# Evidence Tables

Evidence Table 1 Study Descriptions and Results: Behavioral Treatments^*^

Study | Methods^**^ | Participants | Interventions | Outcomes | Results | Dropouts/Notes
Anderson, Basker, and Dalton, 1975 | SPPG QS: 2 (r, ndb, dd) | N =47 Age: N/S % female N/S Migraine; history ≥ 1 yr Chron: N/S Rec: N/S; England | Prochlorperazine (Stemetil^®^): n =24; taken as prophylactic in 5-mg doses 4 x/day for 1 mo, then 2 x/day for 11 mo; ergotamine to be taken at first warning of impending attack Hypnotherapy: n = 23; ≥ six sessions (length N/S) for 10–14 days; pts were treated with hypnotherapy& taught self-hypnosis skills; daily home practice of self-hypnosis | HA frequency: No. of HAs/mo Frequency of incapacitating HAs: No. of patients experiencing Grade 4 HAs (on 4-point pain intensity scale) HA data recorded by therapist 1 x/mo throughout 1-yr treatment period; no daily HA diaries kept by pts. Initial 6-mo pretreat. data were obtained by pt’s global assessment of HA frequency & intensity. | Patients in the hypnotherapy group reduced HA frequency better (not significantly) during the first 6-mo treatment period than did the group taking Stemetil^®^ (p = 0.06). From pretreat. to 1 yr, the hypnotherapy group showed significant reductions in HA frequency (p < 0.005), whereas the Stemetil^®^ group showed no significant changes (p < 0.30). The hypnotherapy group also reduced HA frequency significantly more during the second 6-mo treatment period than it had during the first 6-mo period (p < 0.01). | Dropouts: 0 Efficacy results not based on daily HA recordings; no. of HAs during treatment period recorded at once-a-month sessions with therapist; pretreat. data based on patient’s global assessment of HA frequency & intensity
Andrasik, Blanchard, Neff, et al., 1984 | SPPG QS: 2 (r, ndb, dd) | N = 63 Age: N/S % female N/S Migraine (n = N/S) or migraine + TTH (n = N/S), as diagnosed by psychologist and neurologist Chron: N/S Rec: “Successfully treated” pts (PMR) & “successes & failures” (thermal BF) from previous study (Blanchard, Andrasik, and Neff, 1982); pts from that study recruited from stress disorders clinic in U.S. | Regular contact (“minimal treatment” of thermal BF or relax.): n = 16; 10–15 min, 1 x/mo x 6 mo Booster treatment (more extensive treatment of thermal BF or relax.): n = 15; “full sessions” (length N/S), 1 x/mo x 6 mo; received additional training in “treatment benefiting them most” No treatment provided during months 7–12 Home practice: Daily (time N/S) | HA index: Mean daily HA activity score per week (range: 0–20); composed of HA intensity, frequency, & other variables Both groups monitored HAs daily by diary for 4 wks (pretreat.) & 12 mo (treatment); a subjective assessment (by pt & by “significant other”) of HA improvement was also obtained by questionnaire at end of months 3, 6, & 12. | Authors reported that neither treatment was significantly better than the other at reducing HA index (p-value not given). However, HA index improved in each group from pre- to posttreat. and from pretreat. to each of the 3, 6, & 12-mo f/up periods (p < 0.01, ea. group, ea. period). Eighty percent of pts (12/15) in the “booster” group and 69% of pts (11/16) in the “regular contact” group remained significantly improved at 1 yr (HA index reduced ≥ 50% from pretreat.). | Dropouts: 32 (13/63 bef. treatment; also, 13/29 from “regular” & 6/21 from “booster” groups not included in final analyses) This trial excluded thermal BF & relax. pts who failed previous treatment.
Andrey-chuk and Skriver, 1975 | SPPG QS: 2 (r, ndb, dd) | N = 33 (See note) Age: N/S 85.7% female Migraine Chron: N/S Rec: Publicity in local news media in U.S. | Self-hypnosis: n = 10; 45 min 1 x/wk x 10 wks Thermal BF + relax. (AT phrases): n = 9; 45 min total session 1 x/wk x 10 wks (BF treatment in 15-min periods with short breaks between periods) BF for alpha enhancement: n = 11 (excluded) Home practice: Both groups 2 x/day (time N/S) | HA index: Av. weekly rating; composed of HA duration & intensity HA intensity recorded hourly on 5-point scale Both groups monitored HAs daily by diary for 6 & 10 wks during pretreat. & treatment, respectively. | There were no significant differences between groups for reductions in HA index (p-value not significant). However, the thermal BF group showed a nonsignificant trend toward providing results better than those of the self-hypnosis group. Both groups showed significant reductions in HA index from pre- to "posttreat." (thermal BF, p = 0.01; self-hypnosis, p = 0.025). (Posttreat. data were calculated from the last 5 wks of the 10-wk treatment period.) | Dropouts: 3 We excluded one group (n = 11) treated with BF for "alpha enhancement."
Barrios, 1980 | SPPG QS: 2 (r, ndb, dd) | N = 24 Age: 36.6 100% female Physician diagnosis of migraine; ≥ 1–2 HAs/wk for ≥ 2 yrs Chron: 16.9 Rec: Ads in univ. & city newspapers in U.S. | Relax. (PMR): n = 8; pts treated in groups of five; total session: 45–60 min 2 x/wk x 4 wks Thermal BF + AT phrases: n = 7; pts treated in dyads; treatment session: 15 min BF + 15 min AT phrases 2 x/wk x 4 wks Social skills (beh. self-mgmt) training: n = 9; pts treated in groups of five; total session: 45–60 min 2 x/wk x 4 wks Home practice: All groups, 1/2 hr, 2 x/day (BF group with equipment) | M frequencyt^†^: No. of migraine days/mo HA (all types) frequency: No. of HA days/mo HA intensity: Recorded on 4-point scale (time N/S) daily All groups monitored HAs daily by diary for 4, 4, and 4 wks during pretreat., treatment, and f/up, respectively. | No group was significantly better than any other at reducing any of the HA variables (p-values not given). All treatment groups combined reduced M frequency and HA intensity significantly from pre- to "posttreat." (p < 0.01 and p < 0.001, respectively). | Dropouts: 0 This study's 4- wk "f/up" period is analogous to the "posttreat." period typical of other studies.
Bild and Adams, 1980 | SPPG QS: 2 (r, ndb, dd) | N = 21 Age: 37.6 (range: 21–62) 70% female Migraine (Ad Hocl. ≥ 4 attacks/mo for ≥ 2 yrs; no prophylactic meds Chron: 22.1 Rec: News-paper ad & physician referrals in U.S. | WL (control): n = 6 EMG BF: n = 6; ten 30-min BF sessions, 2–3 sessions/wk; therapist N/S BVP BF: n = 7 (excluded) Home practice: N/S | HA frequencyt^†^: No. of HAs/wk HA intensity: Measured daily (no. of times N/S) on 4-point scale HA duration: No. of hrs of HA activity per wk All groups monitored HAs daily by diary for 6, 4–5, & 6 wks for pretreat., treatment, & posttreat., respectively. | For reducing HA frequency, the EMG BF treatment was not significantly better than the WL group (p-value not given). Although HA frequency declined in both groups, neither treatment showed a statistically significant reduction from pre- to posttreat. (p-values not given). | Dropouts: 2 A BVP group (n = 7) was excluded from our analysis.
Study 1 Blanchard, Andrasik, Appelbaum, et al., 1985 Study 2 Blanchard, Appelbaum, Guamieri, et al., 1988 (Study 2 reports 1- and 2-yr f/up data on pts from Study 1.) | Study 1 SPPG QS: 2 (r, ndb, dd) | Study 1 M-only (Ad Hoc) N = 43 Age: 37.1 (range: 20–60) 71% female Chron: 18.8 Rec: N/S; U.S. Mixed M + TTH (Ad Hoc) N = 60 Age: 37.4 (range: 18–65) 77% female Chron: 17.4 Rec: N/S; U.S. Study 2 1 yr: N = 39 2 yrs: N = 33 | Study 1 Relax. (PMR) + thermal BF (clinic-based): n = 21 (M), 22 (mixed); 16 sessions (time N/S) over 8 wks, with thermal BF for last 10 sessions (tot. contact: 11.4 hrs) Relax. (PMR) + thermal BF (home-based): n = 18 (M), 26 (mixed); three clinic visits, approx. 1 x/4wks, + two 10–15 min phone consultations between visits (tot. contact: 2.6 hrs) Home practice: Both groups, daily (time N/S), with tapes & equipment | Study 1 HA index: Av. daily HA score/wk (range: 0–20), composed of HA intensity & duration HA intensity recorded 4 x/day on 6-point scale Both groups monitored HAs daily by diary for 4, 8, 4 wks for pretreat., treatment, & posttreat., respectively; 1- and 2-yr f/ups were conducted. | Study 1 Authors reported that for both HA groups (M-only and mixed M + TTH) neither treatment was significantly better than the other at reducing HA index (no p- values given). However, each treatment showed a highly significant reduction in HA index from pre- to posttreat. (M-only: clinic-based, p < 0.001; home- based, p < 0.01; mixed M + TTH: clinic-based, p<0.01; home-based, p<0.001). For M-only pts, 56% (10/18) of pts in the home-based group and 43% (9/21) in the clinic-based group improved (showed a ≥ 50% reduction in HA index from pre- to posttreat.). For mixed M + TTH pts, 54% (14/26) in the home-based group and 55% (12/22) in the clinic-based group improved. Study 2 Follow-up studies conducted after Study 1 ended showed that there were no significant differences in improvement between treatment groups at 1 or 2 yrs (no p-values given). However, there were significant improvements for both groups combined in HA index from pretreat. to 1- and 2-yr f/ups (p < 0.001, both cases). There was also an overall improvement: 69% (27/39) of pts at 1 yr and 61% (20/33) of pts at 2 yrs had obtained a ≥ 50% reduction in HA index. | Study 1 Dropouts: 4 (M- only); 12 (mixed M + TTH) Study 2 Dropouts: 28 (1-yr f/up); 6 (2-yr f/up)
Blanchard, Appelbaum, Nicholson, et al., 1990 | SPPG QS: 2 (r, ndb, dd) | N = 97 Age: 40.3 (range: 21–67) 76.3% female Migraine (n = 45) or mixed migraine + TTH (n = 31) (both Ad Hoc); ≥ 1 M/mo for previous 4–6 mo Chron: 17.3 Rec: Media ads; physician, friend, & self-referrals; U.S. | WL (control): n = 17 Thermal BF + relax. (PMR) -“Home- based”: n = 30; three sessions over 8 wks + two telephone contacts (av. 216 min/pt total contacts) Thermal BF + relax. + cog. ther. - “Home - based”: n = 29; same design/schedule as for other BF group plus cog. ther. training (two additional office visits & additional phone calls - avo 330 min/pt total contacts) Both treatment groups of “minimal therapist- contact” design Home practice: Both BF groups daily (time N/S) - PMR for first 4 wks, hand-warming for second 4 wks of treatment | HA index^†^: Composed of HA intensity, duration, & frequency ratings. Calculated by adding 28 values from 1 wk and dividing by 7 to obtain average daily HA activity score (range 0 to 20) HA intensity measured 4 x/day on 6-point scale All groups monitored HAs daily by diary for 4, 8, & 4 wks for pretreat., treatment, & posttreat., respectively. Successfully treated pts & pts who refused additional treatment were followed up at 3 mo. | The thermal BF + relax. treatment was significantly more effective than WL(p = 0.011) at reducing HA index, but it was not significantly better than thermal BF + relax. + cog. therapy (no p-value given). Authors reported that because of the small sample size the difference in improvement between the active groups did not appear to be clinically meaningful. Each BF group showed a significant reduction in HA index from pre- to posttreat. (p = 0.024 for the “without cog. ther.” BF group; p = 0.008 for the “with cog. ther.” BF group). The WLgroup showed no significant reduction in HA index over the same period (no p- value given). | Dropouts: 21
Blanchard, Appelbaum, Radnitz, et al., 1990 | SPPG QS: 2 (r, ndb, dd) | N = 148 Age: 38.6 {range: 21–61) 78.3% female Migraine (n = 74) (Ad Hoc); ≥ 1 HA/mo in last 6 mos & ≥1 HA in last mo; ormixed migraine + TTH (n = 42) (Ad Hoc); 3 TTH days/wk for past 6 mo & “some HAs” on ≥ 12 days in last mo Chron: 15.6 Rec: N/S; U.S. | WL (control): n = 30 Pseudomeditatlon (placebo): n = 24; 35–40 min total sessions 2 x/wk x 8 wks; body awareness + mental control training - pts told “not to relax”; home practice: 20 min/day during treatment phase Thermal BF + relax. (PMR): n = 32; 30–35 min treatment sessions 2 x/wk x 8 wks (6 sessions PMR; 10 sessions TBF); home practice: 20–25 min/day with thermometer during treatment phase Thermal BF + relax. (PMR) + cog. ther.: n = 30; 30–35 min treatment sessions 2x/wk x 8 wks (6 sessions PMR; 10 sessions TBF) + 15–30 min longer for some sessions + training in self-coping strategies; home practice: Same as thermal BF + relax.-only, plus cog. therapy “homework” | HA index^†^: Av. daily HA activity, obtained by summing 28 ratings of HA intensity, duration, & frequency from 1 wk & dividing by 7 HA intensity measured 4 x/day on 6-point scale All groups monitored HAs daily by diary 4, 8, & 4 wks pretreat., treatment, & posttreat., respectively. “Successfully treated” pts were followed up at 3, 6, & 12 mo. | The thermal BF groups combined reduced HA index from pre- to posttreat. significantly better than did the WL group (p = 0.004). The pseudomeditation group also improved compared to WL (p-value not given). There were no significant differences in efficacy among the three active groups. The three active groups each reduced HA index significantly from pre- to posttreat. (both thermal BF groups, p < 0.001, ea. case; pseudomeditation, p < 0.05). The WL group showed no significant reductions over this period (p-value not given). | Dropouts: 32
Blanchard, Nicholson, Radnitz, et al.,1991 | SPPG QS: 2 (r, ndb, dd) | N = 71 Age: 39.2 (range: 23–61) 78.0% female Migraine (n = 37) or mixed migraine + TTH (n = 22) (both Ad Hoc); no prophylactic meds Chron: 19.5 Rec: N/S; U.S. | WL (control): n = 13 Thermal BF (+ AT phrases) with no home practice: n = 23; one 24-min (16-min w/BF; 8 min without) session 2 x/wk x 6 wks Thermal BF (+ AT phrases) with home practice: n = 23; same treatment design/schedule as for thermal BF immed. above, except for addition of 20 min/day home practice with equipment | HA index^†^: Weekly index calculated by summing 28 HA intensity ratings per wk & dividing by 7. Comprises HA intensity (rated 4 x/day on 6-point scale) & duration Active groups monitored HAs daily by diary 4, 6, & 4 wks during pretreat., treatment, & posttreat., respectively; the WL group did so for 4 wks during pretreat. & 8 wks during treatment. | Each thermal BF group reduced HA index significantly better than did the WL group (p < 0.05, each comparison). Neither BF group was significantly more effective than the other (p-value not given). Both active groups reduced HA index significantly from pre- to posttreat. (with home practice: p = 0.007, without home practice: p = 0.034). The WL group showed an increase in HA index from pre- to posttreat. at a level that was not statistically significant. Authors also reported that 52% (12/13), 48% (11/23), and 8% (1/8) of pts improved (i.e., achieved a ≥ 50% reduction in HA index score from pre- to posttreat.) in the thermal BF with home practice, thermal BF without home practice, and WL groups, respectively. | Dropouts: 12
Study 1 Blanchard, Theobald, Williamson, et al., 1978 Study 2 Silver, Blanchard, Williamson, et al., 1979 (Study 2 is a 1-yr f/up of pts from Study 1.) | Study 1 SPPG QS: 2 (r, ndb, dd) | Study 1 N = 37 Age: 38.7(range: 21–77) 83.3% female Migraine; ≥ 2 attacks/mo Chron: N/S Rec: Newspaper & t.v. ads; U.S. Study 2 N = 18 | Study 1 WL (control): n = 10 Relax. (PMR) + home practice: n = 10; 30-min treatment 2 x /wk for 6 wks; home practice: 20–30 min/day Thermal BF + A T (relax.) + home practice: n = 10; 30-min treatment 2 x /wk for 6 wks; home practice: 5–10 min, 2–3 x /day Study 2 Relax. (PMR) + home practice: n = 9 Thermal BF + AT (relax.) + home practice: n = 9 | Study 1 HA index^†^: Obtained by summing a pt’s HA ratings ea. wk and dividing by 28 (HA rating is pain intensity recorded 4 x /day by pt on 6-point scale) HA frequency: No. of “discrete” HAs/wk (must have recorded “no pain” bef. & aft. ea. HA) Each of the above measures was derived from the last 2 wks of pretreat. (averaged) and the last 2 wks of treatment (averaged). Overall HA status: Rating of HA reduction in intensity & frequency on 4-category scale All groups monitored HAs daily by diary for 4, 6, & 12 wks for pretreat., treatment, & f/up, respectively. | Study 1 Mean HA index and frequency scores were reported only on a graph (difficult to read data precisely). Authors reported that for HA index, the active groups were each significantly more effective than the WL group (p < 0.05, both cases). There were no statistically significant differences between thermal BF & relax. (no p-value given). For reductions in HA index from pre- to posttreat., only the relax. group produced statistically significant results (p < 0.001). However, all three groups reduced HA frequency significantly over this period (BF & relax.: p < 0.001, both cases; WL, p < 0.05). Study 2 There were no significant differences between the two treatment groups for reducing either HA index or frequency (p-values not given). Both groups reduced HA index and frequency significantly from pretreat. to 1-yr f/up (p < 0.01, each variable). | Study 1 Dropouts: 7 4 pts had TTHs as well as attacks of migraine
Brown, 1984 | SPPG QS: 2 (r, ndb, dd) | N = 39 Age: 38(range: 18–73) 89.7% female Migraine; ≥ 4 attacks/mo Chron: 90% ≥ 5 yrs Rec: Media ads; U.S. | Subconscious reconditioning (placebo):n = 13; pts were shown relaxing scenes/slides Response group: n = 13; visualized relaxing scenes with accompanying responses (e.g., deep breathing, muscular relax.) Stimulus group: n = 13 (excluded) All groups treated during five 1-hr sessions for 4 wks. All tested bef. & aft. treatment to determine ability to control pain (with hands in cold water) Home practice: N/S | HA index^†^: Defined as sum of intensity ratings for period (baseline, treatment, f/up) divided by no. of days in period. Intensity rated by pts every 2 hrs (scale not given) HA frequency: Sum of HAs during period, divided by no. of days in period HA intensity: Intensity ratings for period divided by no. of intensity ratings in period All groups monitored HAs daily by diary for 4, 4, & 8 wks for pretreat., treatment, & f/up, respectively. | The author included HA index & frequency in a composite of HA variables. The two active groups did not differ significantly from each other for percentage improvement of HA variables from pretreat. to treatment or from pretreat. to f/up (p> 0.05, both time periods). For percentage improvement of HA variables combined from pretreat. to treatment, the active groups combined showed significant improvement over the placebo group (p < 0.01). From pretreat. to f/up, the active groups combined again showed significantly greater improvement (for all HA variables) over the placebo group (p < 0.05). | Dropouts: 0 Note: We excluded from analysis a “stimulus group” treatment (n = 13) because it did not meet our inclusion criteria.
Study 1 Daly, Donn, Galliher, et al.,1983 Study 2 Daly, Zimmerman, Donn, et al., 1985 (Study 2 is a 12-mo f/up of pts from Study 1.) | Study 1 SPPG QS: 1 (nr, ndb, dd) | Study 1 N = 34 Age: 38.2 80.4% female Classic or common migraine Chron: 19.0 Rec: Ads in univ. public’s & locally; univ. health ctr. & physician referrals; U.S. Study 2 N = 31 | Study 1 Relax. (PMR) (control) + AT phrases: n = 11 EMG BF + AT phrases: n = 10 Thermal BF + AT phrases: n = 10 All groups treated during nine ½-hr sessions over 5 wks Home practice: All pts asked to practice 2 x /day without equipment. | Study 1 HA index^†^: Av. hourly HA intensity over life of HA (HA intensity ratings on 6-point scale gathered 4 x /day). HA frequency: No. of hrs/mo of HA All pts monitored HAs daily by diary for “several wks” (pretreat.), 5 wks, & 3 mo for pretreat., treatment, & f/up, respectively. | Study 1 There were no significant differences among the three groups (p = 0.245) for reducing HA index. No pairwise comparisons were reported. Ea. group reduced HA index significantly from pre- to posttreat. at 5 wks (p < 0.05, ea. case). Study 2 There were no significant differences among the treatments at 12 mo for reductions in HA index (no p- values given). Authors stated that, on average, at 1 yr pts had maintained the reductions in HA index gained at 3 mo. in all three treatments. | Study 1 Dropouts: 3 Low quality score (1).
Friedman and Taub, 1984 | SPPG QS: 2 (r, ndb, dd) | N = 76 (See note) Age: 38.4 (range: 18–55) 82.9% female Migraine (physician diagnosis); ≥ 2 attacks/mo Chron: 17.2 (range: 1–44) Rec: Newspaper ads & physician referrals; U.S. | WL (control): n = 10; one session, then HA monitoring only for 3 mo Relaxation: n = 8; home practice: 15–20 min/day Hypnosis (high susceptibility), with thermal imagery: n = 6 (excluded) Hypnosis (high susceptibility), without thermal imagery: n = 9 (excluded) Hypnosis (low susceptibility), with thermal imagery: n = 7 (excluded) Hypnosis (low susceptibility), without thermal imagery. n = 8 (excluded) Thermal BF + AT phrases: n = 7; home practice: 10–20 min/day The BF and relax. groups received five 1-wk sessions (three for treatment); all but WL received self-hypnosis training Home practice: BF & relax. groups, 2 x /day (BF: 10–20 min; relax.: 15–20 min) and at HA onset for 1 yr | HA frequency: Calculated as “number of HA quarters per week” HA intensity: Defined as “highest HA intensity rating/wk” & derived from pain intensity scores recorded 4 x /day on 6-point scale Both active groups monitored HAs daily by diary for 3 wks pretreat. & 3 wks treatment, and throughout a 1-yr f/up; the WL group recorded HAs for 12 wks only. | Authors did not report between-group results for changes in HA frequency HA frequency did not change significantly in the WL group from pretreat. to 3 mo (no p-value given). Authors did not report whether or not they analyzed results for the active groups separately over this period. However, from 6 to 12 mo, the active groups combined reduced HA frequency significantly (p < 0.01). (The WL group provided no data beyond 3 mo.) | Dropouts: 8 (from analyzed groups); 13 (from groups not analyzed) We excluded four hypnosis treatment groups (total n = 43) because allocation of subjects to sthose groups was based on hypnotic susceptibility testing, which might have confounded the treatment effect.
Gauthier, Côté, and French, 1994 | SPPG QS: 2 (r, ndb, dd) | N = 17 Age: 36.4 (range: 23–43) 100% female Migraine Chron: 20.7 (range: 4–40) Rec: From general population, method N/S; Canada | Thermal BF without home practice: n = 9 ; two 20-min sessions/wk x 6 wks (in groups of four to five) Thermal BF with home practice: n = 8; two 20-min sessions/wk x 6 wks (in groups of four to five); home practice: One 20-min or two 10-min periods/day | HA index: Daily average level of HA activity. Obtained from diary of HA intensity measured on 6-point scale 4 x /day Both groups monitored HAs daily by diary for 5, 6, & 5 wks during pretreat., treatment, & posttreat., respectively. | For reducing HA index, authors reported that the “home practice” thermal BF group was significantly better than the “no home practice” group (p < 0.05). The home practice group showed a significant reduction in HA index from pre-to posttreat. (p < 0.05), but the no home practice group did not (no p-value given). | Dropouts: 0
Gauthier, Lacroix, Côté, et al., 1985 | SPPG QS: 3 (r+, ndb, dd) | N = 22 Age: 35.0 (range: 19–48) 100% female Migraine; ≥ 2 attacks/mo for ≥ 2 yrs; no prophylactic or abortive meds Chron: N/S Rec: General community ads in Canada | WL (control): n = 7 Thermal BF: n = 8; two 20–60 min treatment sessions per wk x 6 wks (session duration determined by performance; interspersed with baseline recordings); one test session (tested 2 x /40 min; no BF) bef. & aft. treatment period BVP BF: n = 7 (excluded) Home practice: For BF groups, 20 min/day (once for 20 min or twice for 10 min) | HA frequency^†^: Total no. of discrete HAs (HA preceded & followed by HA intensity rating of 0) HA intensity: Total of all intensity ratings (rated daily [time N/S] on 6-point scale) All groups monitored HAs daily by diary 5, 6, & 5 wks for pretreat., treatment, & posttreat., respectively. | There were no significant differences in efficacy between the two BF groups for reducing either HA index or frequency (p-values not given). However, both BF groups combined were significantly better at reducing HA intensity, but not frequency, from pre- to posttreat. than was the WL group (p < 0.001). | Dropouts: 0 We excluded from analysis a BVP BF group (n = 7). Post hoc power was small (≤ 0.20).
Holroyd, France, Cordingley, et al., 1995 | Matched pairs QS: 2 (r, ndb, dd) | N = 33 Age: 31.7 (range: 16–52) 79% female Diagnosis of migraine (IHS) from 3 sources; ≥ 1 attack/mo; history ≥ 1 yr; no prophylactic meds for ≥ 6 mo bef. treatment Chron: 15.2 (range: 1–47) Rec: Univ. research clinic; U.S. | Relax. + thermal BF: n = 14; two sessions (time N/S) 4 wks apart, followed by a third session + two telephone consultations (tot.: 12 wks) Relax. + thermal BF + propranolol Hcl: n = 13; same treatment design/schedule as for above therapy, plus 60, 120, or 180 mg of propranolol HCl daily (dose increased as tolerated); at 1 mo, max. tolerated dose was determined, then continued for 2 mo Home practice: Both groups, with tapes, manuals, & equipment (time N/S) | HA index: Av. daily HA activity, comprising HA intensity, duration, & frequency. Calculated as sum of four daily recordings averaged over ea. wk (range: 0–40) HA intensity recorded 4 x /day on 11-point scale Both groups monitored HAs daily by diary for 4 & 12 wks for pretreat. & treatment, respectively; the percentage change in HA index was assessed by physician at end of treatment. | Authors reported that pts who received relax.+ thermal BF + propranolol decreased HA index significantly better than did pts who received relax. + thermal BF alone (p < 0.05). The relax. + thermal BF + propranolol group reduced HA index significantly from pre- to posttreat. (p < 0.05); the relax. + thermal BF also reduced HA index levels over this period, but not at a statistically significant level (p < 0.10). At posttreat., 92% of pts (12/13) who received the combined treatment and 57% of pts (8/14) who received relax. + thermal BF alone showed at least a 50% reduction in HA index. There was a statistically significant difference between the two proportions (p<0.05). | Dropouts: 6 Dropouts were replaced in this matched-pair study.
Study 1 Holroyd, Holm, Hursey, et al., 1988 Study 2 Holroyd, Holm, Penzien, et al., 1989 (Study 2 was a 3- year f/up of the 21 pts successfully treated [achieved ≥ 50% reduction in HA index] in Study 1.) | Study 1 SPPG QS: 2 (r, ndb, dd) | Study 1 N = 41 Age: 33 (range: 19–56) 65% female Migraine (n = 21) or mixed migraine + TTH (n = 20); ≥ 1 migraine attack/mo; recurrent HAs for ≥ 1 yr; no prophylactic meds ≥ 2 mo + no abortive meds ≥ 1 mo bef. treatment Chron: 14 (range: 2–37) Rec: HA pts at univ. research clinic; U.S. Study 2 N = 21 | Study 1 Ergotamine tartrate + compliance training (home-based): n = 18; one clinic visit (time N/S) bef. & aft. month 1 & aft. month 2 of treatment + phone calls received aft. wks 2 & 6; meds given at first session & usage monitored aft. month 1; home practice N/S Thermal BF + relax. (home-based): n = 19; one clinic visit (time N/S) bet. & aft. month 1 & aft. month 2 of treatment + phone calls received aft. wks 2 & 6; home practice: Books & tapes (time N/S) Study 2 Ergotamine + compliance training: n = 11 Thermal BF + relax.: n = 8 | Study 1 HA index: Sum of four daily HA intensity ratings averaged over ea. wk (range: 0–40) (HA intensity rated 4 x/day on 11-point scale) HAs monitored daily by diary 4 x/day for 4, 8, & 4 wks for pretreat., treatment, & posttreat., respectively, & for a 3-wk f/up period 4 mo aft. last treatment. Three years later, authors followed up on the “successfully treated” pts. Study 2 Data were obtained from 3-yr treatment histories (from 19 pts) + 1-mo HA diary (from 16 pts; 8 in ea. group). | Study 1 Authors reported that both treatment groups reduced HA index significantly from pre- to posttreat., but neither group was better than the other (no p-values given). Fifty-three percent (10/19) of pts treated with thermal BF + relax. and 61 % (11/18) of pts treated with ergotamine + compliance training showed at least a 50% reduction in HA index from pre- to posttreat. The ergotamine tartrate group, however, showed greater improvement in the first month of treatment than did the thermal BF group (p < 0.05). Study 2 HA index levels at posttreat. and at 3-yr f/up did not differ significantly between the two groups (no p- values reported). All pts had lower HA index levels at posttreat. and 3-yr f/up than they had reported prior to treatment (p < 0.01, ea. period). At the 3-yr f/up, half of pts in each treatment group continued to show a ≥ 50% reduction in HA index. Seventy-five percent of pts (6/8) in the thermal BF group continued to use thermal BF, whereas < 20% of pts (2/11) in the ergotamine tartrate group continued to use their treatment (although half were using some kind of medication). The difference between the two proportions was statistically significant (p < 0.05). | Study 1 Dropouts: 4 Study 2 Small sample size (19), and high dropout rate (22/41 original patients)
Ilacqua, 1994 | SPPG QS: 2 (r, ndb, dd) | N = 40 Age: N/S % female N/S Migraine Chron: N/S Rec: Volunteers at clinic in Canada | WL (control): n = 10 (excluded) Combined (thermal BF + guided imagery): n = 10; six 20-min sessions Guided imagery: n = 9; six 20-min sessions Thermal BF + relax.: n = 9; six 20-min sessions No home practice | HA frequency: Definition N/S HAs not monitored by diary. Questionnaires administered bef. & aft. treatment | The author reported that no group was significantly better at reducing HA frequency than any of the others, and there were no significant reductions in HA frequency from pre- to posttreat. in any of the treatment groups (no p-values given). | Dropouts: 2 A WL group (n = 10) was excluded because it was not a credible control (six 20- min sessions “just relaxing”) HA data not recorded on daily basis
Janssen and Neutgens, 1986 | SPPG QS: 2 (r, ndb, dd) | N = 33 Age: 33.4 63% female Classic or common migraine (n = 12) or migraine + TTH (n = 19), as diagnosed by two psychologists & two psycho- physiologists Chron: 11.4 Rec: Referral by GPs in The Netherlands | Relax. (AT phrases): n = N/S; 1 hr/wk x 12 wks Relax. (PMR): n = N/S; 1 hr/wk x 12 wks Pts treated in small groups (3–5 pts) Home practice: Both groups, 2 x/day (time N/S) | HA index: Composed of HA intensity, frequency, & duration ratings HA frequency: Definition N/S HA intensity: Recorded every 4 hrs on 11-point scale Both groups monitored HAs daily by diary for 2–1/2,12, & 2 wks for pretreat., treatment, & “posttreat.,” respectively (prior to f/up 3 mo later). | From treatment (wks 12 & 13) to f/up (wks 25 & 26), there were no significant differences between the two groups for reducing HA index in M-only pts (p = 0.634) or in pts with mixed M + TTH (p = 0.052). The AT phrases treatment, however, showed a trend toward being more effective than the PMR treatment. Authors reported pre-and posttreat. results for HA index only on graphs from which it was difficult to determine precise data. Both groups reduced HA index from pretreat. to f/up (no p-values given). | Dropouts: 2 of total of 43 (not clear whether dropouts from M-only, M + TTH, or TTH-only groups) The trial also included a group of pts (n = 10) with TTH only; this group is not considered here.
Jurish, Blanchard, Andrasik, et al., 1983 | Matched pairs QS: 2 (r, ndb, dd) | N = 45 Age: 37.3 76% female Migraine (n = 20) or migraine + TTH (n = 20) (both Ad Hoc) Chron: 19.6 Rec: Clinic specializing in nonpharm HA treatment; U.S. | Thermal BF + relax. (PMR) (clinic-based): n = 10 (M), 11 (M + TTH); sixteen 1-hr total sessions over 8 wks (BF training, ten 20-min sessions over 5 wks; relax. training, 12 sessions) (mean therapist time: 11.4 hrs) Thermal BF + relax. (PMR) (home-based, “minimal therapist-contact”): n = 10 (M), 9 (M + TTH); two 60-min & one 3D-min clinic visits + two telephone consultations (mean therapist time: 2.6 hrs) Home practice: Both groups, 1 x/day with tapes, manuals, & equipment | HA index: Av. daily HA activity score per wk (range: 0–20) HA intensity recorded 4 x/day on 6-point scale Both groups monitored HAs daily by diary for 4, 8, & 4 wks for pretreat., treatment, & posttreat., respectively. | Authors reported that an ANOVA analysis showed a nonsignificant difference between the two treatment groups for reducing HA index from pre- to posttreat. (p = 0.09). Each group achieved clinically meaningful improvements (i.e., showed a ≥ 50% reduction from pre- to posttreat.) in HA index, with the minimal-contact group being significantly more effective (p < 0.01). Of the M-only pts, 70% (7/10 pts) in the minimal-contact group and 40% (4/10 pts) in the clinic-based group improved. Of the M + TTH pts, 89% (8/9 pts) in the minimal-contact group and 64% (7/11 pts) in the home-based group improved. | Dropouts: 5
Kewman and Roberts, 1980 | SPPG QS: 1 (nr, ndb, dd) | N = 40 Age: 40 (range: 21–75) 100% female Migraine; history ≥ 3 yrs; ≥ 72 HAs; ≥ 2 HAs/mo in last yr Chron: N/S Rec: News- paper articles & physician referrals; U.S. | WL (control): n = 11 (pts familiar with BF allocated to this group) Thermal BF (increase temp.): n = 11; 6-wk pretreat.; 9-wk-and-1-day treatment (10 sessions, approx. 7 days apart: three 10-min. periods of training/session); 6-wk posttreat.; undergrad. student; clinic; home practice: Amount N/S Thermal BF (decrease temp.): n = 12; same treatment schedule/design as for thermal BF “increase temp.” above | HA frequency^†^: No. of HAs/wk HAs were monitored daily by two types (N/S) of diaries for 6, 9, & 6 wks during pretreat., treatment, & posttreat., respectively. | Authors found no significant differences between the thermal BF (increase temp.) and WL groups for reducing HA frequency. Neither group reduced HA frequency significantly from pre-to posttreat. (no p-values given). | Dropouts: 6 Pts were nonrandomly allocated to the WLgroup; moreover, we excluded the thermal BF “decrease temperature” group from our analysis; therefore, we designated this study as “non-randomized” for the comparison between the thermal BF “increase temperature” and WL groups. Low quality score (1).
Lacroix, Clarke, Bock, et al., 1983 | SPPG QS: 1 (nr, ndb, dd) | N = 27 Age: 41.4 74.1 % female Migraine Chron: 19.5 Rec: Physician referral; 23/27 pts were in-patients at a rehab center and had major injuries in addition to migraine; Canada | Relax. (PMR): n = 7; same treatment & test session design/schedule as for EMG BF except relax. tape used instead of BF during treatment; no tape used during test sessions EMG BF: n = 9; 15-min treatment sessions 9 x/wk x 2 wks with BF + test sessions without BF (to generalize learning) at beg. & end of ea. treatment session + two test sessions (20–25 min ea.) bef. & aft. treatment wk 1 and aft. treatment wk 2 Thermal BF: n = 8; same treatment & test session design/schedule as for EMG BF All patients treated in group sessions Home practice: Asked of all groups (time N/S), but equipment not provided | HA frequency: Obtained by interviews Global subjective rating of improvement: Obtained by interviews; reported on 5-point scale Pretreat. & posttreat. are the time points bef. & aft. treatment, not week-long phases; f/up is at 6–8 wks & again at 6 mo. HAs not monitored by pt diaries. Data gathered by interviews & phone calls pre- & posttreat. | Results were reported only on graphs (difficult to read data precisely). There were no significant differences among the groups at posttreat., but all groups combined decreased HA frequency significantly from pre- to posttreat. (p < 0.01). | Dropouts: 3 Efficacy results not based on daily HA recordings. Low quality score (1).
Lake, Rainey, and Papsdorf, 1979 | SPPG Qs: 2 (r, ndb, dd) | N = 24 Age: 33.0 (range: 20–56) 79.1 % female Migraine; ≥ 3 severe HAs/mo; no preventive BF therapies Chron: 13.8 yrs (range: 6 mo - 37 yrs) Rec: Newspaper ad & article; local physicians; U.S. | WL (control): n = 6 EMG BF: n = 6; eight to ten 30-min sessions 2 x/wk x 4 wks + one 30-min session at 3-mo f/up Thermal BF + relax.: n = 6; same treatment schedule/design as for EMG BF, immed. above Thermal BF + cognitive (RET): n = 6; same treatment schedule/design as for EMG BF, above, plus three 30–40-min RET sessions with therapist Home practice: For three BF groups 10–20 min, 2 x/day | HA index^†^: Derived from HA intensity ratings HA intensity: Recorded daily ea. hr on 6-point scale All groups monitored HAs daily by diary 4, 4, & 12 wks for pretreat., treatment, & f/up, respectively. | For HA index, “mean daily HA ratings” for each group were reported only on a graph (difficult to read data precisely). Analyses of the three active groups separately showed only EMG BF to be superior to WL (p = 0.0076). For reductions in HA Index from pretreat. to 3-mo f/up, authors found BF (all three BF groups collapsed) to be superior to WL (p = 0.048). | Dropouts: 0
Machado and Gómez de Machado, 1985 | SPPG QS: 2 (r, ndb, dd) | N = 19 Age: 33.8 (range: 14–56) 100% female Migraine; history;≥ 2 yrs; ≥ 2 HAs/wk; no prophylactic meds Chron: 12.3 Rec: Referral by physicians in Honduras | WL (control): n = 7; pts received two baseline treatment sessions Relax. (modified PMR): n = 5; eight 25-min sessions 1 x/wk x 10 wks Relax. (modified PMR) + thermal BF: n = 7; eight 25-min sessions 1 x/wk x 10 wks Home practice: Both active groups, daily with tapes & as needed | HA index: Composed of HA intensity & duration HA frequency: Definition N/S All three groups monitored HAs daily by diary for 1 wk pretreat.; active groups also did so for ≈ 8 wks treatment; active groups were followed up 1 mo aft. treatment. | An ANOVA analysis showed that the two active groups were significantly better than the WL group for HA index (p < 0.05) and frequency (p < 0.01). There were no significant differences between the two active treatments for these outcomes (no p-values given). Both active groups reduced HA index and frequency significantly from pre- to posttreat., but the WL group did not (no p-values given; results reported on a figure from which it is difficult to obtain precise data). | Dropouts: 0 Unpublished manuscript
Mathew, 1981 | SPPG QS: 2 (r, ndb, dd) | M-only N = 340 Age: 35.5 (av.) 93.5% female Chron: N/S Rec: N/S; U.S. Mixed M + TTH N = 375 Age: 40.2 (av.) 95.5% female Chron: N/S Rec: N/S; U.S. | Control (abortive admin. of ergotamine + analgesic): n = 33 (M), 35 (mixed); total ergotamine intake ≤ 6 mg/wk Propranolol: n = 38 (M), 38 (mixed); 20 mg 3 x/day initially; increased to 40 mg 3 or 4 x/day within first month of treatment, as tolerated Amitriptyline: n = 32 (M), 31 (mixed); 25 mg/day for 2 wks, then increased to 50–75 mg/day in first month, as tolerated Biofeedback (combined EMG + thermal) + relax. (AT phrases): n = 31 (M), 31 (mixed); ten 1-hr sessions over 6 mo; home practice: ≤ 30 min, 1 x/day Propranolol + amitriptyline: n = 38 (M), 36 (mixed); combined using dosages described above Propranolol + biofeedback (as above): n = 33 (M), 34 (mixed); combined using dosage and procedure described above Amitriptyline + biofeedback (as above): n = 38 (M), 39 (mixed); combined using dosage and procedure described above Propranolol + amitriptyline + biofeedback (as above): n = 30 (M), 37 (mixed); combined using dosages and procedure described above | HA index. Av. weekly index, derived from HA frequency & intensity ratings HA frequency: Definition N/S, but recorded daily HA intensity: Definition N/S, but recorded daily All groups monitored HAs by diary for 1 mo (pretreat.) and 6 mo (treatment). | Improvement was expressed as the percentage of change in HA index scores from pretreat. to the average of the last 3 mo of treatment. For the migraine-only pts, each active group improved significantly better than did the control group (no p- values given). The improvement percentages ranged from 35–74% for the active groups, compared with 20% for the control group. The biofeedback-alone treatment resulted in 35% improvement, which was significantly better than that of the control group (no p-value given). The combination of propranolol + biofeedback yielded the best improvement (74%); amitriptyline + biofeedback showed a 73% improvement. The propranolol-alone group improved by 62%, and the amitriptyline-alone group improved by 42%, with the former treatment being significantly better than the latter (p < 0.01). For the mixed HA pts, the most effective treatment was the combination of biofeedback with amitriptyline plus propranolol (76%). Amitriptyline alone was significantly better than propranolol alone (60% vs. 52%) (p < 0.01). A combination of propranolol and amitriptyline was superior to either of those drugs singly (p < 0.01). Biofeedback alone yielded a 48% improvement. When biofeedback was added to each of the drug therapies, the percentages of improvement increased in each group (from 52% to 62% for propranolol; from 60% to 66% for amitriptyline). | Dropouts: 67 (M), 94 (mixed) 18 (M) and 29 (mixed) pts dropped out because of “untoward side effects.” Most adverse events occurred in the control group.
McGrady, Wauquier, McNeil, et al., 1994 | SPPG QS: 2 (r, ndb, dd) | N = 23 Age: 42 (range: 29–59) 87.0% female Migraine Chron: N/S Rec: Volunteers | Self-relax. (placebo): n = 12; two sessions (time N/S) over 8–12 wks Thermal BF + EMG BF + AT phrases (relax.): n = 11; 12 sessions (four EMG, eight thermal BF; time N/S) over 8–12 wks Home practice: Both groups, 10–15 min 2 x/day; BF group with relax. tape, self-relax. group without tape | HA index^†^: Composed of HA frequency, intensity, & duration ratings & compiled as “average total pain score for pre- and posttest intervals” Both groups monitored HAs daily by diaries 15–24 days (pretreat.); 8–12 wks (treatment); & at end of treatment and 4–6 wks after treatment for 2 wks (posttreat.). | Authors reported that the BF group decreased HA index more than did the placebo group (no p-value given). Both groups together showed a trend toward significance for reducing HA index from pre- to posttreat. (p-value between 0.05 & 0.10). The BF group as a whole decreased pain scores by 35%; the placebo group increased pain scores by 7.7%. Six of 11 pts (55%) in the BF group and 3/12 pts (25%) in the WL group improved (i.e., decreased pain by ≥ 50% from pre- to posttreat.). | Dropouts: 0 We classified the active treatment as “thermal BF + relax.” in our analysis because there were more BF than EMG sessions.
Mitchell and Mitchell, 1971 | Study 1 SPPG QS: 2 (r, ndb, dd) Study 2 SPPG QS: 1 (nr, ndb, dd) | Study 1 N = 17 Age: 22.8 (range: 17–44) % female N/S Migraine Chron: 8 (range: 3–19) Rec: Volunteer univ. staff & students in Australia Study 2 N = 20 Age: 27.9 (range: 18–55) % female N/S Migraine Chron: 9.2 (range: 2–18) Rec: Volunteer univ. staff, students, & others in Australia | Study 1 WL (control): n = 3 (excluded) Relax. (PMR) application: n = 7; fifteen 50–60 min sessions (2 x/wk, with 2 days between sessions); first three sessions for PMR training, remaining sessions for application-of-skills training; home practice: Three 10-min periods/day Relax. + cog. ther. (combined desensitization): n = 7; fifteen 50–60 min sessions (2 x/wk, with 2 days between sessions); simultaneous training in applied relax., desensitization, & assertiveness therapy; home practice: N/S Study 2 WL (control): n = 5; monitoring HAs only Relax. + systematic desensitization: n = 5; fifteen 50–60 min sessions Combined desensitization (previous pharm. therapy treatment): n = 5; same treatment design/schedule as for Study 1 Combined desensitization (no previous pharm. therapy treatment): n = 5; same treatment design/schedule as for Study 1 | Study 1 HA frequency: Number of HAs over 32 wks HA intensity recorded on 10-point scale at onset of ea. HA All groups monitored HAs at onset by diary for 8, 8, & 16 wks for pretreat., treatment, & f/up, respectively. Pts were interviewed after 8, 16, 24, &32 wks. Study 2 HA frequency: Same as for Study 1 Same HA monitoring design as for Study 1 | Study 1 There was a significant difference in reduction of HA frequency between the combined desensitization and the WL groups (p < 0.01), but no significant difference was found between the relax. application and the WL groups (p = 0.47). The combined desensitization treatment was significantly better than the relax. treatment (p < 0.01). Pts in the combined desensitization group showed a significant reduction in HA frequency from pretreat. to 32 wks (p-value not given), but there were no significant changes for the relax. application group during this period (no p-value given). Results were not provided for changes over time for the WL group. For reductions in HA frequency, 100%,71%, and 33% of pts in the combined desensitization, relax. application, and WL groups, respectively, improved from pretreat. to 32 wks. The threshhold for deciding improvement was not stated. Study 2 The “combined desensitization (no previous pharm. therapy)” group reduced HA frequency from pretreat. to 32-wk f/up better than did any of the other three groups (p < 0.05, ea. comparison). Both combined desensitization groups together reduced HA frequency over time significantly better than did the systematic desensitization and the WL groups (p < 0.001). There were no significant differences between the two latter groups (no p-value given). Results for changes in HA frequency from pretreat. to f/up within ea. group were reported only on a figure from which it is difficult to determine precise data. | Study 1 Dropouts: 0 WL group excluded because it had <5 pts. One pt was nonrandomly allocated to control group because of unusually high number of HAs during pretreatment. Study 2 Dropouts: 0 Five pts (with history of nonresponsiveness to pharm. therapy) were placed in combined desensitization (previous pharm. therapy) group. Both combined desensitization groups were excluded. Low quality score (1). score
Mullinix, Norton, Hack, et al., 1978 | SPPG QS: 2 (r, ndb, dd) | N = 12 Age: N/S (range: 16–58) 58.3% female Migraine; ≥ 2 attacks/mo Chron: N/S Rec: Referred by physicians due to frequent HAs or poor response to therapy; U.S. | False thermal BF (placebo): n = 5; same treatment design/schedule as for thermal BF, except that BF signal was controlled by investigator to consistently indicate increasing temperature Thermal BF: n = 6; pts treated in six 30-min sessions over 2–3 wks + session at 1, 2, & 6 wks posttreat.; home practice: 2 x/day without equipment | HA intensity^†^: Percentage improvement of average weekly HA intensity from pre- to posttreat. (HA intensity recorded hourly for 24 hrs on 3-point scale) HAs monitored by all pts hourly by diary for 24 hrs for ≥ 5 wks (mean 8.8 wks) during pretreat. (wks N/S), treatment (2–3 wks), & posttreat. (3 mo), respectively. | Authors reported that the two groups showed similar improvements: 33% (2/6) of pts in the thermal BF group and 20% (1/5) of pts in the false thermal BF group improved (i.e., HA intensity diminished ≥ 50% from pre- to posttreat.). | Dropouts: 1 Due to small sample size, the study lacked adequate power to detect differences between the two treatments.
Nicholson and Blanchard, 1993 | Matched pairs (7 pairs with multiple pretreat. periods [2 or 4 wks], across subjects) QS: 2 (r, ndb, dd) | N = 19 M-only (Ad Hoc) N = 4 Age: 68.8 (range: 63–75) 83% female Chron: 38.5 (range: 0–48) Rec: N/S; U.S. M+TTH(Ad Hoc) N = 6 Age: 64.7 (range: 61–69) 50% female Chron: 38.8 (range: 15–65) Rec: N/S; U.S. | WL (control): n = 5 Relax. (PMR) + cog. ther. (either stress-coping or problem-solving) + thermal BF: n = 5; twelve 90-min sessions over 8 wks (2 x/wk for wks 1, 2, 5, & 6; 1 x/wk for other 4 wks); six sessions, PMR + cog. ther.; six sessions EMG BF (16 min) + cog. ther. Home practice: Relax. group, 2 x/day, with equipment | HA index^†^: Sum of all 28 HA intensity ratings per pt ea. wk, divided by 7 (range: 0–20) HA intensity recorded 4 x/day on 6-point scale Both groups monitored HAs daily by diary for 4 or 12, 8, & 4 wks for pretreat., treatment, & posttreat., respectively. | Of five pairs, 3/5 pts receiving the active treatment improved (obtained a ≥ 50% reduction in HA index from pre- to posttreat.), while HA activity for the WL member of the pair remained unchanged. Of the same five pairs, 1/5 pts receiving the WL treatment improved while the member of the pair receiving the active treatment worsened. The authors did not report the statistical significance of these results. | Dropouts: 5 of total of 19 (not clear whether dropouts from M-only, M + TTH, or TTH-only groups) Dropouts were replaced in this matched-pair study. The trial also included a group of pts (n = 4) with TTH only; this group is not considered here. All pts “elderly” (age range: 61–75)
Passchier, van der Helm-Hylkema, and Orlebeke, 1985 | SPPG QS: 1 (nr, ndb, dd) | N = 59 Age: 36.5 (range: 17–56) 63% female Migraine (Ad Hoc); history ≥ 2 yrs; ≥ 2 HAs/mo or ≥ one long HA period/mo; no nonmed. HA treatment in last yr Chron: N/S Rec: News-paper ads in The Netherlands | WL (control): n = 11 Stress-coping + relax. (PMR): n = 11 Stress-coping + relax. (PMR) + thermal BF: n = 15 Stress-coping + relax. (PMR) + BVP BF: n = 14 (excluded) All active groups treated during twenty 45-min sessions (first 10 sessions, 2 x/wk; next 10, 1 x/wk) Home practice: N/S | HA index: Calculated as product of HA frequency, intensity, & duration. HA frequency: Definition N/S HA intensity: Recorded 3 x/day on 5-point scale All groups monitored HAs daily by diary for 4, 15, & 4 wks for pretreat., treatment, & posttreat., respectively. | Authors reported that there were no significant differences among the treatments for reducing HA index or frequency (no means or p-values given). The authors measured HA index, but did not report whether or not it changed significantly from pre- to posttreat. (no p-value given). | Dropouts: 8 A BVP BF group with 14 pts was excluded. Low quality score (1).
Penzien, Johnson, Carpenter, et al., 1990 | SPPG QS: 2 (r, ndb, dd) | N = 22 Age: N/S % female N/S Migraine Chron: N/S Rec: N/S; U.S. | Relax. + thermal BF + cog.-beh. coping skills (home-based): n = 11; three sessions (time N/S) x 6 wks + telephone consultations; therapist N/S; home practice (amt. N/S) Propranolol (60–160 mg inderal^®^ LA): n = 11; two sessions x 6 wks + telephone consultations | HA index: Definition N/S Both groups monitored HAs daily by diary for 4, 6, & 4 wks for pretreat., treatment, & posttreat., respectively. | Authors reported that there were no significant differences between treatments for reductions in HA index (mean reductions: behavioral, 42%; propranolol, 44%). Both groups reduced HA index significantly from pre- to posttreat. (p-values not given). Forty-six percent (5/11) and 55% (6/11) of pts in the behavioral and propranolol groups, respectively, were improved (achieved> 50% reduction in HA index from pre- to posttreat.). Thirty-six percent (4/11) and 18% (2/11), respectively, were moderately improved (achieved 25–50% reduction), and 18% (2/11) and 27% (3/11), respectively, were not improved (< 25% reduction). | Dropouts: 0 Abstract reporting prelimiinary results
Reading, 1984 | SPPG QS: 1 (nr, ndb, dd) | N = 28 Age: 45.6 100% female Migraine (diagnosed by physician) Chron: 23.4 Rec: Physician referral; England | False EMG BF (placebo): n = 7; mixture of false BF with “true” BF (max. of 3 s/min of true BF when pt exceeded a set threshhold) EMG BF (frontalls): n = 7 Thermal BF: n = 7 Skin conductance BF: n = 7 (excluded) All groups: Ten 40-min total sessions over 5 wks (two 10-min BF periods per session) Home practice N/S | HA frequency: Total no. of HAs/wk Pts recorded HA intensity as mild, moderate, or severe (scale N/S). All groups monitored HAs at onset daily by diary for 5, 5, & 5 wks during pretreat., treatment, & posttreat., respectively. | Authors reported that there were no significant differences in efficacy among the groups but that all groups improved significantly over time (no p-values given). For all treatment groups combined, there was a significant reduction in HA frequency from pre- to posttreat. (p < 0.001), in the number of severe HAs each wk (p < 0.05), and in the number of moderate HAs each wk (p < 0.001). There was no significant change in the number of mild HAs during this period. Authors did not report whether or not they analyzed results for the groups individually. | Dropouts: 0 The trial contained a skin conductance SF group with 7 pts that we excluded from our analysis. Low quality score (1).
Richardson and McGrath, 1989 | SPPG QS: 2 (r, ndb, dd) | N = 51 Age: 35.6 (range: 23–48) 85.1 % female Common migraine; ≥2 HAs/mo for ≥3 mos; no classical migraine symptoms; no prophylactic meds within last mo; no cog.-beh. ther. for HAs within 5 yrs Chron: 16.7 (range: 2–40) Rec: Media ads, nurses, & physicians in Canada | WL (control): n = 17; HM daily for 4 wks pre- & posttreat., but none during 8 wks that others were receiving treatment Cog. ther. + relax. (PMR) - "Minimal therapist contact": n = 15; 1/2 hr bef. treatment & once during 5th wk of treatment Cog. ther. + relax. (PMR) -"Clinic-based": n = 15; 60 min 1 x /wk x 8 wks Home practice: For cog. ther. groups, daily practice with book + tapes | HA index: Composed of HA frequency, duration, intensity, et al. (HA intensity rated 4 x /day on 6-point scale) HA frequencyt: Definition N/S All groups monitored HAs daily by diary for 4 wks during pretreat. & posttreat.; the cog. ther. groups also did so during the 8 treatment wks. Six months aft. treatment, all groups were asked to monitor HAs for 4 more wks. | For reductions in HA frequency from pre- to posttreat., there were significant differences between ea. of the active groups and the WL group (no p- values given), but none between the two active groups (no p-value given). The two active groups combined reduced HA frequency significantly over that period (no p-values given). | Dropouts: 4
Study 1 Sargent, Solbach, Coyne, et al., 1986 Study 2 Solbach, Sargent, and Coyne, 1984 (Study 2 was a study of a subset of pts from Study 1 with menstrual migraine.) | Study 1 SPPG QS: 3 (r+, ndb, dd) | Study 1 N = 193 Age: 35.7 83.8% female Classical or common migraine (Ad Hoc); ≥4 M days/mo for 6 mo/yr for 2 yrs; meds fail to relieve at least 1 severe M in past 2 yrs Chron: 17 Rec: Physician referral, self-referral; U.S. Study 2 N = 83 Age: 31 100% female As above, but only those attacks occurring 3 days bef. or aft. menstrual flow, or during flow, were considered Chron: 13 | Study 1 WL (control): n = 34; daily records; inactive during training Autogenic phrases: n = 34; daily records + AT phrases EMG SF: n = 34; daily records + AT phrases + EMG BF; six sessions with EMG BF, two without Thermal SF: n = 34; daily records + AT phrases + thermal BF; six sessions with thermal BF, two without Pretreat. (all groups): 2 x /4 wks (20 min sitting quietly); treatment: 5 min stabilization, then 15 min practice, 8 x /8 wks; f/up: 12 x /24 wks (no BF during f/up) Home practice: For three active groups, 15 min/day during treatment & f/up periods without equipment Study 2 WL (control): n = 21 Autogenic phrases: n = 22 EMG BF: n = 24 Thermal BF: n = 16 Same treatment schedule/design as for Study 1 | Study 1 HA index: Included HA intensity, frequency, duration. Computed as daily 4-wk average of all HA variables HA frequency: Total days HA reported (≥ one HA/day counted as one HA) HA intensity: Reported on 100-point scale All groups monitored HAs daily by diary for 4, 8, & 24 wks during pretreat., treatment, & f/up, respectively. Study 2 Same outcome variables as for Study 1, but only for Ms occurring 3 days bef. or aft. menstrual flow, or during flow | Study 1 For reductions in HA frequency from pretreat. to f/up, there were no significant differences between thermal BF vs. AT phrases and EMG combined (p = 0.082) or between AT phrases vs. EMG BF (p-value not given). No other pairwise comparisons were reported. All four groups reduced HA frequency from pretreat. to f/up, with the three active groups combined being significantly better than WL (p = 0.016). Results were not reported for ea. separate group. Study 2 Authors reported that there were no significant differences among the four groups for reductions in HA frequency. However, all groups combined significantly reduced HA frequency from pretreat. to f/up (p < 0.001). | Study 1: Dropouts: 57 24 pts also had TTH, but TTH activity “minimal,” and pts able to distinguish attacks of M from TTHs
Sorbi and Tellegen, 1984 | SPPG QS: 2 (r, ndb, dd) | N = 29 Age: 40.8 (range: 20–59) 76.2% female Migraine (n = 14)or migraine + TTH (n = 7) (both Ad Hoc); ≥ 2 attacks/mo Chron: 16.9 (range: 6–35) Rec: Physician referrals in The Netherlands | AT relax. + cog. ther. (stress-coping): n = 10; nine 50-min sessions x 5 wks (relax.) + nine 1-hr sessions weekly (cog. ther.) AT relax. + cog. ther. (stress-coping) + thermal BF: n = 11; same treatment design/schedule as above, except BF training incorporated into relax. portion (8/9 relax. sessions were for BF); BF portions: 4D-min total (two 15-min treatment periods with two 5-min baseline periods per session) Home practice: Both groups, 2 x/day (time N/S) | HA frequency^†^: Calculated by dividing the sum of discrete HAs by the number of days of a given time period. To be counted, a HA must have had a rating of zero bef. & aft. ea. HA. HA intensity: The sum of HA intensity values divided by the number of discrete HAs HA intensity recorded daily ea. hr on 5-point scale Both groups monitored HAs daily by diary for 4, 5 (relax.) or 8 (cog. ther.), and 4 wks for pretreat., treatment, and posttreat., respectively, and for a 7-mo f/up period. | Neither treatment group was significantly better than the other at reducing HA frequency (p = 0.98). Results were similar, whether pts received thermal BF treatment or not. However, both treatment groups significantly reduced HA frequency from pre- to posttreat. (“with thermal BF,” p < 0.05; “'without thermal BF,” p < 0.01). | Dropouts: 8
Study 1 Sorbi and Tellagen, 1986 Study 2 Sorbi, Tellagen, and Du Long, 1989 (Study 2 isa 3-yr f/up of pts from Study 1.) | Study 1 SPPG OS: 2 (r, ndb, dd) | Study 1 N = 32 Age: 35.8 (range: 19–59) 82.8% female Migraine (Ad Hoc); ≥ 2 attacks/mo for ≥ 1 yr Chron: 17.3 (range: 1–52) Rec: GP & self-referrals; The Netherlands Study 2 N = 27 | Study 1 Relax. training (AT phrases): n = 13; 1 hr/wk x 9; relax. training first half of session, then application training; home practice: 2 x/day (time N/S) with tapes Cog. ther. (stress mgmt/self-coping training): n = 16; 1 hr/wk x 9; skills acquisition, rehearsal, application, & self-monitoring; home practice: As often as possible Study 2 Relax. training (AT phrases): n = 10 Cog. ther. (stress mgmt/self-coping training): n = 14 No new treatment/training given to either group. Psychologists conducted 9D-min f/up interviews. | Study 1 M frequency^†^: Sum of M attacks divided by number of days experienced. “Migraine attacks” defined as HAs with HA intensity rating ≥ 3, accompanied by nausea or vomiting & unilaterally located at least once. To be counted as an attack, HA had to be preceded & followed by one day without HAs. M intensity: Sum of HA intensity ratings for “migraine attacks” (defined above), averaged per attack, divided by number of attacks. HA intensity recorded 4 x/day on 5-point scale (HAs with rating of “1,” the lowest rating, were excluded from analyses) Total HA frequency: Sum of all HAs (including those rated 1 or 2), divided by number of days Both groups monitored HAs daily by diary for 8, 8, & 8 wks for pretreat., treatment, & posttreat., respectively, and for 4 wks after posttreat. (then followed up≈ 6–7 mo later). Study 2 Same outcome measures & descriptions as for Study 1 | Study 1 Authors reported results for between-group comparisons only on a figure (difficult to read data precisely). They stated that “[t]he effects did not differ between the two types of training.” For M frequency, M intensity, and total HA frequency, both treatment groups showed significant reductions from pre- to posttreat. The relax. training group reduced M frequency by 40% (p < 0.01), and the cog. ther. group by 31 % (p < 0.05). Study 2 Authors reported that neither treatment group was significantly better than the other at reducing any of the HA variables from pretreat. to 3-yr f/up. However, at 3 yrs both groups had maintained the previously achieved reductions in M frequency (relax., 38%; cog. ther., 36%). The percentage of improvement from pretreat. to f/up was statistically significant in ea. case (p < 0.05, relax.; p < 0.01, cog. ther.). | Study 1 Dropouts: 3 3 pts had TTHs in addition to Ms. Study 2 Dropouts: 3 2 pts had TTHs in addition to Ms.
Sovak, Kunzel, Sternbach, et al., 1981 | SPPG QS: 2 (r, ndb, dd) | N = 58 Age: N/S (range: 30–57) 100% female Common or classical migraine; no HAs between attacks; severe, “vascular-type” pain; no meds for BF group Chron: N/S Rec: Pain treatment center; U.S. | Drug therapy (propranolol + analgesics): n = 20; dosages and treatment regimen not described Thermal BF + relax. (AT phrases): n = 28; eight to ten 45-min sessions (2 x/wk for first 2 wks, then at intervals increasing until there were 4 wks between the last two sessions); home practice: 2 x/day with equipment + 10-min tape | HA index: Composed of HA incidence, intensity (scale N/S), & duration Both groups monitored HAs daily by diary during treatment (length of time N/S). | Authors did not report results for comparisons between the two treatment groups for HA index. Changes from pre- to posttreat. for each group were reported only on figures from which it was difficult to determine precise results. Fifty-four percent (15/28) and 45% (9/20) of pts in the thermal BF and drug therapy groups, respectively, improved with treatment. Authors did not report the cutoff percentage used to determine “improvement.” | Dropouts: 10
Wittchen, 1983 | SPPG QS: 2 (r, ndb, dd) | N = 30 Age: 39 (range: 24–53) 76.7% female Common or classical migraine (n = 21), mixed migraine + TTH (n = 7), or cluster (n = 2) (all Ad Hoc) Chron: 57% > 10 yrs Rec: Referral by GP or specialist; Germany | WL (control): n = 10; HM only; recordings monitored by psychologist 1 x/mo x 4 mo Psychological therapy: n = 10; pts treated in groups of three to five; six 90-min sessions biweekly + four sessions 1 x/wk; treated in three phases (instruction, training, practice in relax. & self-coping skills) Acupuncture therapy: n = 10 (excluded) Home practice: N/S | HA frequency: Mean number of HA days/mo HA intensity: Mean weekly intensity score; patients graded attacks on a scale of 1–5 (slight, moderate, relatively severe, severe, unbearable) Frequency of disabling HAs^†^: Mean number of days/wk with severe performance impairments HAs monitored daily by diary for 4, 8, & 4 wks during pretreat., treatment, & a 4-wk f/up, respectively; there was also an 8-wk f/up. | Authors did not report between-group results for changes in HA frequency and intensity from pretreat. to posttreat. However, ea. active group reduced HA frequency and intensity significantly from pre- to posttreat. (p < 0.05, ea. treatment group, ea. variable), but the WL group did not (p-value not given). Similar results were reported for pre- to post-treatment changes in the frequency of disabling HAs. | Dropouts: 0 2 cluster HA pts included Pts referred for trial because of history of “severe long-term” M attacks. Acupuncture treatment group excluded from meta-analysis because there were no other trials comparing a behavioral treatment with acupuncture.

* Key: admin. = administrative; aft. = after; ANOVA = analysis of variance; AT. = autogenic training; av. = average; bef. = before; beg. = beginning; beh. = behavioral; BF = biofeedback; BVP = blood volume pulse; chron = chronicity; cog. = cognitive; ctr. = center; db = double-blind; dd = dropouts described; diag. = diagnostic; dnd = dropouts not described; ea. = each; EEG = electroencephalogram; EMG = electromyograph; excl. = exclusion; f/up = follow-up; GP = general practitioner; grad. = graduate; HA = headache; HCl = hydrogen chloride; hist. = history; HM = headache monitoring; hr = hour; hypn. = hypnosis; IHS = International Headache Society; immed. = immediately; incl. = inclusion; LA = long-acting; M = migraine; max. = maximum; meds = medications; mg = milligram; mgmt. = management; mo = month; N = number of patients; ndb = not double-blinded; nonmed. = nonmedical; nonpharm. = nonpharmacological; nr = not randomized; N/S = not specified; pharm. = pharmacological; PMR = progressive muscle relaxation; posttreat. = posttreatment; pretreat. = pretreatment; pt = patient; public’s = publications; QS = quality score; r = randomized; r+ = randomization described; rec = recruitment setting; rehab. = rehabilitation; relax. = relaxation; RET = Rational Emotive Therapy; s = seconds; SD = standard deviation; SE = standard error; SPPG = single-period parallel group; TBF = thermal BF; temp. = temperature; ther. = therapy; tot. = total; TTH = tension-type headache; t.v. = television; undergrad. = undergraduate; univ. = university; U.S. = United States; wk = week; WL = wait-listed; yr = year

** Quality score numbers: One point (for a total of five) is allocated for meeting (or subtracted for failing to meet) the following criteria: randomized (gains 1 pt if trial is described as such); randomized+ (gains 1 point if method of randomization is described); randomized- (loses 1 point if method of randomization is inadequate); double-blind (gains 1 point if trial is described as such); double-blind+ (gains 1 point if trial provides adequate description of double-blinding); double-blind- (loses 1 point if method of double-blinding is inadequate); dropouts described (gains 1 point if dropouts/withdrawals are described)

† Outcome measure analyzed in this report

Evidence Table 2 Efficacy of Behavioral Treatment^*^

Study | Treatment Type | # Imprv’d/N (%)^**^ | Mean Values | | | | OC Measure | Effect Size
Study | Treatment Type | # Imprv’d/N (%)^**^ | N | Before Treatment | After Treatment | % Improvement | OC Measure | Effect Size
Anderson, Basker, and Dalton, 1975 | Prochlorperazine (Stemetil^®^) | - | 24 | - | - | - | - | -
Anderson, Basker, and Dalton, 1975 | Hypnotherapy | - | 23 | - | - | - | - | -
Andrasik, Blanchard, Neff, et al., 1984 | Regular contact (thermal BF or relax. [PMR]) | 11/16 (69%) | 16 | - | - | - | - | -
Andrasik, Blanchard, Neff, et al., 1984 | Booster treat. (thermal BF or relax. [PMR]) | 12/15 (80%) | 15 | - | - | - | - | -
Andreychuk and Skriver, 1975 | Self-hypnosis | - | 10 | 87.5 | 55.1 | 0.37 | HI | -
Andreychuk and Skriver, 1975 | Thermal BF + relax. (AT phrases | - | 9 | 132.1 | 24.1 | 0.82 | HI | -
Barrios, 1980 | Relax. (PMR) | - | 8 | 4.00 | 3.75 | 0.06 | HF | †
Barrios, 1980 | Thermal BF + AT phrases | - | 7 | 6.57 | 4.00 | 0.39 | HF | †
Barrios, 1980 | Social skills (beh. mgmt) | - | 9 | 6.89 | 3.56 | 0.48 | HF | †
Bild and Adams, 1980 | Control (WL) | - | 6 | 2.40 | 2.00 | 0.17 | HF | †
Bild and Adams, 1980 | EMG BF | - | 6 | 2.20 | 1.40 | 0.36 | HF | 0.79 (0.08 to 1.49)
Blanchard, Andrasik, Appelbaum, et al., 1985 (Migraine-only) | Relax. (PMR) + thermal BF (clinic-based) | 9/21 (43%) | 21 | 2.29 | 1.42 | 0.38 | HI | -
Blanchard, Andrasik, Appelbaum, et al., 1985 (Migraine-only) | Relax. (PMR) + thermal BF (home-based) | 10/18 (56%) | 18 | 2.26 | 1.21 | 0.46 | HI | -
Blanchard, Andrasik, Appelbaum, et al., 1985(Mixed M + TTH) | Relax. (PMR) + thermal BF (clinic-based) | 12/22 (55%) | 22 | 4.26 | 2.65 | 0.38 | HI | -
Blanchard, Andrasik, Appelbaum, et al., 1985(Mixed M + TTH) | Relax. (PMR) + thermal BF (home-based) | 14/26 (54%) | 26 | 4.60 | 2.54 | 0.45 | HI | -
Blanchard, Appelbaum, Nicholson, et al., 1990 | Control (WL) | 2/17 (12%) | 17 | 2.48 | 2.31 | 0.07 | HI | †
Blanchard, Appelbaum, Nicholson, et al., 1990 | Thermal BF + relax. (PMR) (home-based) | 12/20 (40%) | 30 | 3.02 | 2.34 | 0.23 | HI | 0.01 (−0.59 to 0.60)
Blanchard, Appelbaum, Nicholson, et al., 1990 | Thermal BF + relax. (PMR) + cog. ther. (home-based) | 13/29 (45%) | 29 | 3.21 | 2.31 | 0.28 | HI | 0 (−0.6 to 0.6)
Blanchard, Appelbaum, Radnitz, et al., 1990 | Control (WL) | 6/30 (20%) | 30 | 2.51 | 2.53 | −0.01 | HI | †
Blanchard, Appelbaum, Radnitz, et al., 1990 | Placebo (pseudomeditation) | 9/24 (38%) | 24 | 3.07 | 1.94 | 0.37 | HI | 0.18 (−0.36 to 0.72)
Blanchard, Appelbaum, Radnitz, et al., 1990 | Thermal BF + relax. (PMR) | 17/32 (53%) | 32 | 3.53 | 2.05 | 0.42 | HI | 0.15 (−0.35 to 0.65)
Blanchard, Appelbaum, Radnitz, et al., 1990 | Thermal BF + relax. (PMR) + cog. ther. | 15/30 (50%) | 30 | 3.37 | 1.90 | 0.44 | HI | 0.19 (−0.31 to 0.70)
Blanchard, Nicholson, Radnitz, et al., 1991 | Control (WL) | 1/13 (8%) | 13 | 2.98 | 3.44 | −0.15 | HI | †
Blanchard, Nicholson, Radnitz, et al., 1991 | Thermal BF + relax. (AT phrases) + no home practice) | 11/23 (48%) | 23 | 3.76 | 2.92 | 0.22 | HI | 0.12 (−0.56 to 0.80)
Blanchard, Nicholson, Radnitz, et al., 1991 | Thermal BF + relax. (AT phrases) + home practice) | 12/23 (52%) | 23 | 3.91 | 2.65 | 0.32 | HI | 0.18 (−0.50 to 0.86)
Blanchard, Theobald, Williamson, et al., 1978 | Control (WL) | - | 10 | 0.85 | 0.66 | 0.22 | HI | †
Blanchard, Theobald, Williamson, et al., 1978 | Relax. (PMR) + home practice | 6/11 †† (55%) | 10 †† | 0.98 | 0.17 | 0.83 | HI | 0.88 (−0.4 to 1.8)
Blanchard, Theobald, Williamson, et al., 1978 | Thermal BF + relax. (AT phrases) + home practice | 9/13 †† (69%) | 10^††^ | 0.70 | 0.21 | 0.70 | HI | 0.80 (−0.11 to 1.7)
Brown, 1984 | Placebo (subconscious reconditioning) | - | 13 | 1.00 | 1.07 | −0.07 | HI | †
Brown, 1984 | Response group (relax.) | - | 13 | 1.00 | 0.50 | 0.50 | HI | 1.06 (0.24 to 1.88)
Daly, Donn, Galliher, et al., 1983 | Relax. ([PMR] + AT phrases) | 6/11 (55%) | 11 | 0.68 | 0.63 | 0.08 | HI | †
Daly, Donn, Galliher, et al., 1983 | EMG BF + relax. (AT phrases) | 7/10 (70%) | 10 | 0.59 | 0.25 | 0.58 | HI | †
Daly, Donn, Galliher, et al., 1983 | Thermal BF + relax. (AT phrases) | 8/10 (80%) | 10 | 0.76 | 0.37 | 0.51 | HI | †
Friedman and Taub, 1984 | Control (WL) | - | 10 | - | - | - | - | -
Friedman and Taub, 1984 | Relax. | - | 8 | 26.7 | 25.3 | 0.03 | HF | -
Friedman and Taub, 1984 | Thermal BF + relax. (AT phrases) | - | 7 | 11.3 | 8.9 | 0.21 | HF | -
Gauthier, Côté, and French, 1994 | Thermal BF + no home practice | 2/9 (22%) | 9 | 2.67 | 2.73 | −0.02 | HI | -
Gauthier, Côté, and French, 1994 | Thermal BF + home practice | 5/8 (63%) | 8 | 3.18 | 1.85 | 0.42 | HI | -
Gauthier, Lacroix, Côté, et al., 1985 | Control (WL) | N/S | 7 | 11.8 | 10.2 | 0.14 | HF | †
Gauthier, Lacroix, Côté, et al., 1985 | Thermal BF | 5/8 (63%) | 8 | 13.6 | 5.5 | 0.60 | HF | 0.73 (−0.32 to 1.8)
Holroyd, France, Cordingley, et al., 1995 | Relax. + thermal BF | - | 14 | 5.21 | 2.63 | 0.50 | HI | -
Holroyd, France, Cordingley, et al., 1995 | Relax. + thermal BF + propranolol HCl | - | 13 | 6.11 | 1.83 | 0.70 | HI | -
Holroyd, Holm, Hursey, et al., 1988 | Ergotamine tartrate + compliance training (home-based) | 11/18 (61%) | 18 | 7.55 | 4.81 | 0.36 | HI | -
Holroyd, Holm, Hursey, et al., 1988 | Thermal BF + relax. (home-based) | 10/19 (53%) | 19 | 7.79 | 4.59 | 0.41 | HI | -
Ilacqua, 1994 | Guided imagery | - | 9 | - | - | - | - | -
Ilacqua, 1994 | Combined (thermal BF + guided imagery) | - | 10 | - | - | - | - | -
Ilacqua, 1994 | Thermal BF + relax. | - | 9 | - | - | - | - | -
Janssen and Neutgens, 1986 (Migraine-only) | Relax. (AT phrases) | - | N/S | 0.72 | 0.59 | 0.18 | HI | -
Janssen and Neutgens, 1986 (Migraine-only) | Relax. (PMR) | - | N/S | 0.83 | 0.56 | 0.33 | HI | -
Janssen and Neutgens, 1986 (Mixed M + TTH) | Relax. (AT phrases) | - | N/S | 0.64 | 0.58 | 0.09 | HI | -
Janssen and Neutgens, 1986 (Mixed M + TTH) | Relax. (PMR) | - | N/S | 0.87 | 0.51 | 0.41 | HI | -
Jurish, Blanchard, Andrasik, et al., 1983 | Thermal BF + relax. (PMR) (clinic-based, both HA groups combined) | 11/21 (52%) | 21 | 3.45 | 2.13 | 0.38 | HI | -
Jurish, Blanchard, Andrasik, et al., 1983 | Thermal BF + relax. (PMR) (home-based, minimal therapist-contact, both HA groups combined) | 15/19 (79%) | 19 | 3.59 | 1.47 | 0.59 | HI | -
Kewman and Roberts, 1980 | Control (WL) | - | 11 | 1.23 | 1.0 | 0.19 | HF | †
Kewman and Roberts, 1980 | Thermal BF (increase temp.) | - | 11 | 0.98 | 0.85 | 0.13 | HF | 0.08 (−0.76 to 0.91)
Lacroix, Clarke, Bock, et al., 1983 | Relax. (PMR) | | 7 | 4.00 | 1.50 | 1.63 | HF
Lacroix, Clarke, Bock, et al., 1983 | EMG BF | | 9 | 2.50 | 2.00 | 0.20 | HF
Lacroix, Clarke, Bock, et al., 1983 | Thermal BF | | 8 | 4.00 | 0.55 | 0.86 | HF
Lake, Rainey, and Papsdorf, 1979 | Control (WL) | | 6 | 1.00 | 1.17 | −0.17 | HI
Lake, Rainey, and Papsdorf, 1979 | EMG BF | | 6 | 1.00 | 0.48 | 0.52 | HI | 1.61 (0.31 to 2.91)
Lake, Rainey, and Papsdorf, 1979 | Thermal BF + relax. | | 6 | 1.00 | 0.70 | 0.30 | HI | 1.09 (−0.12 to 2.30)
Lake, Rainey, and Papsdorf, 1979 | Thermal BF + cog. ther. (RET) | | 6 | 1.00 | 0.79 | 0.21 | HI | 0.89 (−.29 to 2.08)
Machado and Gómez de Machado, 1985 | Control (WL) | | 7 | 8.80 | 10.6 | −0.20 | HF
Machado and Gómez de Machado, 1985 | Relax. (modified PMR) | | 5 | 2.60 | 1.20 | 0.54 | HF
Machado and Gómez de Machado, 1985 | Relax. (modified PMR) + thermal BF | | 7 | 6.00 | 0.80 | 0.87 | HF
Mathew, 1981 (Migraine-only) | Control (abortive ergotamine) | | 33 | 3.40 | 2.72 | 0.20 | HI
Mathew, 1981 (Migraine-only) | Propranolol | | 38 | 4.12 | 1.57 | 0.62 | HI
Mathew, 1981 (Migraine-only) | Amitriptyline | | 32 | 3.93 | 2.28 | 0.42 | HI
Mathew, 1981 (Migraine-only) | Biofeedback (thermal + EMG) + relax. | | 31 | 3.50 | 2.28 | 0.35 | HI
Mathew, 1981 (Migraine-only) | Propranolol + amitriptyline | | 38 | 4.08 | 1.47 | 0.64 | HI
Mathew, 1981 (Migraine-only) | Propranolol + biofeedback | - | 33 | 4.22 | 1.1 | 0.74 | HI | -
Mathew, 1981 (Migraine-only) | Amitriptyline + biofeedback | - | 38 | 3.78 | 1.89 | 0.48 | HI | -
Mathew, 1981 (Migraine-only) | Propranolol + amitriptyline + biofeedback | - | 30 | 4.31 | 1.17 | 0.73 | HI | -
Mathew, 1981 (Mixed M + TTH) | Control (abortive ergotamine) | - | 35 | 8.12 | 6.6 | 0.18 | HI | -
Mathew, 1981 (Mixed M + TTH) | Propranolol | - | 38 | 6.7 | 3.24 | 0.52 | HI | -
Mathew, 1981 (Mixed M + TTH) | Amitriptyline | - | 31 | 7.78 | 3.12 | 0.60 | HI | -
Mathew, 1981 (Mixed M + TTH) | Biofeedback (thermal + EMG) + relax. | - | 31 | 8.06 | 4.20 | 0.48 | HI | -
Mathew, 1981 (Mixed M + TTH) | Propranolol + amitriptyline | - | 36 | 7.36 | 2.51 | 0.69 | HI | -
Mathew, 1981 (Mixed M + TTH) | Propranolol + biofeedback | - | 34 | 6.32 | 2.41 | 0.62 | HI | -
Mathew, 1981 (Mixed M + TTH) | Amitriptyline + biofeedback | - | 39 | 7.10 | 2.42 | 0.66 | HI | -
Mathew, 1981 (Mixed M + TTH) | Propranolol + amitriptyline + biofeedback | - | 37 | 7.84 | 1.89 | 0.76 | HI | -
McGrady, Wauquier, McNeil, et al., 1994 | Placebo (self-relax.) | 3/12 (25%) | 12 | 1.19 | 1.24 | −0.04 | HI | †
McGrady, Wauquier, McNeil, et al., 1994 | EMG BF + thermal BF + relax. (AT phrases) | 6/11 (55%) | 11 | 1.28 | 1.00 | 0.22 | HI | 0.11 (−0.71 to 0.93)
Mitchell and Mitchell, 1971 (Study 1) | Relax. (PMR) application | - | 7 | 1.00 | 0.76 | 0.24 | HF | -
Mitchell and Mitchell, 1971 (Study 1) | Relax. + cog. ther. (combined desensitization) | - | 7 | 1.00 | 0.24 | 0.76 | HF | -
Mitchell and Mitchell, 1971 (Study 2) | Control (WL) | - | 5 | 1.00 | 0.93 | 0.07 | HF | -
Mitchell and Mitchell, 1971 (Study 2) | Relax. + cog. ther. (systematic desensitization) | - | 5 | 1.00 | 0.59 | 0.41 | HF | -
Mullinix, Norton, Hack, et al., 1978 | Placebo (false thermal BF) | 1/5 (20%) | 5 | 1.00 | 0.92 | 0.08 | HI | †
Mullinix, Norton, Hack, et al., 1978 | Thermal BF | 2/6 (33%) | 6 | 1.00 | 0.78 | 0.21 | HI | 0.25 (−0.94 to 1.44)
Nicholson and Blanchard, 1993 | Control (WL) | - | 5 | 1.00 | 0.90 | 0.10 | HI | †
Nicholson and Blanchard, 1993 | Relax. (PMR) + cog. ther. (stress-coping or problem-solving) + thermal BF | - | 5 | 1.00 | 0.54 | 0.46 | HI | 0.91 (−0.39 to 2.21)
Passchier, van der Helm-Hylkema, and Orlebeke, 1985 | Control (WL) | - | 11 | - | - | - | - | -
Passchier, van der Helm-Hylkema, and Orlebeke, 1985 | Cog. ther. (stress-coping) + relax. (PMR) | - | 11 | - | - | - | - | -
Passchier, van der Helm-Hylkema, and Orlebeke, 1985 | Cog. ther. (stress-coping) + relax. (PMR) + thermal BF | - | 15 | - | - | - | - | -
Penzien, Johnson, Carpenter, et al., 1990 | Propranolol | 6/11 (55%) | 11 | - | - | - | - | -
Penzien, Johnson, Carpenter, et al., 1990 | Relax. + thermal BF + cog. ther. (coping skills, home-based) | 5/11 (46%) | 11 | - | - | - | - | -
Reading, 1984 | Placebo (false EMG SF) | - | 7 | - | - | - | - | -
Reading, 1984 | EMG SF (frontalis) | - | 7 | - | - | - | - | -
Reading, 1984 | Thermal BF | - | 7 | - | - | - | - | -
Richardson and McGrath, 1989 | Control (WL) | 3/17 (18%) | 17 | 15.53 | 15.20 | 0.02 | HF | §
Richardson and McGrath, 1989 | Cog. ther. + relax. (PMR)-Minimal therapist contact | 5/15 (33%) | 15 | 14.5 | 10.5 | 0.28 | HF | §
Richardson and McGrath, 1989 | Cog. ther. + relax. (PMR)-Clinic-based | 7/15 (47%) | 15 | 15.47 | 8.32 | 0.46 | HF | §
Sargent, Solbach, Coyne, et al., 1986 | Control (WL) | - | 34 | 6.33 | 5.79 | 0.09 | HF | -
Sargent, Solbach, Coyne, et al., 1986 | Relax. (AT phrases) | - | 34 | 6.84 | 5.86 | 0.14 | HF | -
Sargent, Solbach, Coyne, et al., 1986 | EMG BF | - | 34 | 6.95 | 5.27 | 0.24 | HF | -
Sargent, Solbach, Coyne, et al., 1986 | Thermal BF | - | 34 | 6.99 | 5.51 | 0.21 | HF | -
Sorbi and Tellegen, 1984 | Relax. (AT phrases) + cog. ther. (stress-coping) | - | 10 | 0.20 | 0.094 | 0.53 | HF | †
Sorbi and Tellegen, 1984 | Relax. (AT phrases) + cog. ther. (stress-coping) + thermal BF | - | 11 | 0.27 | 0.15 | 0.44 | HF | †
Sorbi and Tellegen, 1986 | Relax. (AT phrases) | - | 13 | 0.19 | 0.11 | 0.40 | HF | †
Sorbi and Tellegen, 1986 | Cog. ther. (stress mgmt) | - | 16 | 0.12 | 0.08 | 0.31 | HF | †
Sovak, Kunzel, Sternbach, et al., 1981 | Drug therapy (propranolol + analgesics) | - | 20 | - | - | - | - | -
Sovak, Kunzel, Sternbach, et al., 1981 | Thermal SF + relax. (AT phrases) | - | 28 | - | - | - | - | -
Wittchen, 1983 | Control (WL) | - | 10 | 3.5 | 3.0 | 0.14 | Freq. of disabling HAs | †
Wittchen, 1983 | Psychological ther. | - | 10 | 2.4 | 1.7 | 0.29 | Freq. of disabling HAs | 0.29 (−0.59 to 1.17)
Wittchen, 1983 | Acupuncture ther. | - | 10 | 3.4 | 1.6 | 0.53 | Freq. of disabling HAs | §§

* Key: AT = autogenic; beh. = behavioral; SF = biofeedback; cog. = cognitive; EMG = electromyograph; freq. = frequency; HA = headache; HCL = hydrogen chloride; HF = headache frequency; HI = headache index; imprv’d = improved; M = migraine; mgmt = management; N = number of subjects; OC = outcome; PMR = progressive muscle relaxation; relax. = relaxation; RET = Rational Emotive Therapy; temp. = temperature; ther. = therapy; treat. = treatment; TTH = tension-type headache; WL = wait-listed

** The “# Imprv’d/N (%)” and “N (Mean Value)” may occasionally differ because the efficacy data for each may have been derived at different times in the study (patients may have dropped out, thus reducing the number).

† Data from trial were included in meta-analysis, but this study does not provide an effect size for a comparison with a control group.

†† Treatment numbers are from a later timepoint than those of “number improved”; numbers do not match because some patients dropped out.

§ Trial was included in meta-analysis, but an effect size could not be calculated because data were stratified by headache severity.

§§ Treatment was discussed in text but not included in the meta-analysis.

Evidence Table 3 Study Descriptions and Results: Physical Treatments^*^

Study | Methods^**^ | Participants | Interventions | Outcomes | Results | Dropouts/Notes
Ceccherelli, Ambrosio, Avila, et al., 1987 | SPPG QS:2 (r, ndb, dd) | N = 30 Age: 38 (range: 16–57) 70% female Common migraine Chron: N/S Rec: N/S; Italy | Placebo = sham acupuncture: n = 15 Acupuncture (using “well-known set of points”): n = 15 Both groups were treated once/wk for 10 wks-no further details provided | Pain intensity: “Remaining pain” scored at end of therapy (10 wks); result described as “good” (remaining pain score between 0–50% of original score), “unsatisfactory” (remaining pain score 51–80% of original score), or “poor” (remaining pain score > 80% of original score) | Pain intensity: 13/15 patients (87%) in the acupuncture group had a “good” result, 1/15 (7%) “unsatisfactory,” and 1/15 (7%) “poor”; in the sham acupuncture group, the corresponding figures were 5/15 (33%), 4/15 (27%), and 6/15 (40%). Linear regression of the weekly sum of daily pain scores showed that genuine acupuncture significantly decreased pain intensity compared with initial pain scores (p <0.001), but that sham acupuncture did not (no p-value reported). “Weekly remaining pain” in the acupuncture group was 15.88% of initial pain; in the sham acupuncture group, it was 49.96% of initial pain. Authors stated that acupuncture was “significantly better” than sham acupuncture for this outcome, but did not report a p-value for this direct comparison. | Dropouts: 0 Abstract reporting few details of methods and results Not clear how the assessment of “remaining pain” related to daily pain scores recorded by patients Not clear how baseline/initial pain scores established
Dowson, Lewith, and Machin, 1985 | SPPG QS: 3 (r+, ndb, dd) | N = 48 Age: 40 (range: 14–68) 83% female Classical or common migraine; ≥ 2 HAs/wk; at least some patients also experienced “simple” HAs Chron: N/S Rec: Two primary care health centers in England | Placebo = mock transcutaneous electrical nerve stimulation (TENS) (no current, but flashing red light): n = 23 Acupuncture (points selected depending on type and distribution of pain and patient’s response; no electrical stimulation used): n = 25 4-wk baseline period, followed by 6-wk treatment period, followed by 24-wk follow-up period Acute and preventive med permitted | Frequency: Number of patients with 50% reduction in frequency in first 4 wks post-treatment, compared with 4-wk baseline period Severity: Number of patients with 50% reduction in average pain intensity in first 4 wks post-treatment, compared with 4-wk baseline period; patients graded HA severity daily on scale of 0–6 (none, very mild, mild, not very severe, quite severe, very severe, almost unbearable) | There was no statistically significant difference between the two treatments for HA frequency: 8/25 patients (32%) in the acupuncture group experienced a reduction of 50% or more in HA frequency post-treatment, as did 6/23 patients (26%) receiving the placebo treatment (no p-value reported). Identical dichotomous results were reported for HA severity: 8/25 patients (32%) in the acupuncture group experienced a reduction of 50% or more in HA severity post-treatment, as did 6/23 patients (26%) receiving the placebo treatment (p = 0.65). | Dropouts: 9 patients (19%) failed to complete the 24- wk follow-up, but were included by investigators in the main efficacy analysis Investigators included data from both migrainous and “simple” HAs and reported that the two types of HA “appeared to respond in the same way to the treatments used”
Forssell, Kirveskari, and Kangasniemi, 1985 | SPPG QS: 3 (r+, db−, dd) | N = 96 Age: 30 (range: 17–52) 88% female Migraine (n = 36), muscle contraction HA (n = 39), or combination HA (n = 21) (all Ad Hoc); most patients had symptoms of, and all had clinical signs of mandibular dysfunction Chron: N/S Rec: Neuro dept outpatient clinic in Finland | Sham occlusal adjustment (superficial contact with nonfunctional surfaces; no splint therapy): overall n = 43; migraine n = 17; mixed HA n = 10 Occlusal adjustment (grinding plus splint therapy, if needed): overall n = 48; migraine n = 18; mixed HA n = 10 1-mo baseline period; period of treatment varied from patient to patient; mean active treatment and follow-up time (± SD) was 8.0 mos (± 2.9) (range: 5–20 mos); mean number of visits was 6.7 (± 2.3) (range: 4–14); duration of individual treatment session varied from 10 to 30 min; mean sham treatment and follow-up time was 3.9 mos (± 2.0) (range: 2–6); total number of visits was 3 in every case but one (mean 2.9 ± 0.2); minimum duration of treatment session was 20 min No prophylactic med allowed; symptomatic med OK | HA frequency: (1) Number of patients with decreased frequency of HA post-treatment; (2) difference in mean HA frequency, pre-and post-treatment HA intensity: (1) Number of patients with decreased intensity of HA post-treatment; (2) difference in mean HA frequency, pre-and post-treatment; severity graded on scale of 1–5 (not described) | We did not consider the categorical data reported on the number of patients with decreased frequency or intensity of HA post-treatment because these data were not based on daily HA recordings, did not meet our ≥ 50% improvement criterion, and were not reported separately for non-TTH patients. Among migraine patients receiving active treatment, mean HA frequency decreased during the first two months of treatment by an average of 2.0 attacks/mo in comparison to the baseline period; among migraine patients in the sham treatment group, the average reduction was 1.0 attack/mo (no variance data reported; no p-value reported). Mixed HA patients receiving the active treatment reported a reduction of 4.4 attacks/mo; those receiving the placebo treatment, a reduction of 3.2 attacks/mo (no variance data reported; no p-value reported). Reductions in HA intensity were small in all groups (no data reported). Investigators concluded that, for patients with migraine only, occlusal adjustment was not superior to the sham treatment. Patients with mixed migraine + TTH responded more favorably. The effect of the active treatment was significantly better than that of the placebo treatment, and both frequency and intensity were reduced (no p-values reported). | Dropouts: 5 (5%), including 1 migraine patient and 1 mixed HA patient
Hesse, Møgelvang, and Simonsen, 1994 | SPPG QS: 2 (r, ndb, dd) | N = 85 Age: 45 (range: 25–70) 84% female Migraine w/or w/o aura (IHS); history ≥ 2 yrs; 2–6 attacks/mo; able to distinguish migraine from TTH Chron: 23.4 yrs (range: 2–55) Rec: News-paper ads or referred by GP; Denmark | Metoprolol + sham acupuncture (metoprolol 100 mg/day + superficial touching of myofascial trigger points in neck region with broad end of needle); n = 39 Placebo tablets + acupuncture (dry needling of myofascial trigger points in neck region; number of trigger points needled per treatment, interval between treatments, and total number of treatments determined individually by therapist): n = 38 4-wk baseline period, followed by 17-wk treatment period; no follow-up Non-trial preventive med and non-trial physical treatments not permitted; symptomatic med OK | HA frequency (medians compared) Global rating of attack (scored for each HA on scale of 1–3: mild, moderate, severe; took into account severity, duration, and associated symptoms; medians compared) HA duration (medians compared) | Both treatment groups exhibited significant reductions in median HA frequency over the course of the trial (p<0.01). There was no significant difference between the two treatments (p>0.20). Metoprolol was significantly better than acupuncture for median global rating of attack (p<0.05). There was no significant difference between the two treatments for median HA duration (p>0.10). Adverse events (AEs): 14/39 patients (36%) taking metoprolol reported AEs on open questioning, compared to 3/38 (8%) receiving acupuncture. | Dropouts: 8 (9%) Non-parametric statistical analysis performed by investigators
Loh, Nathan, Schott, et al., 1984 | CrOv QS: 2 (r, ndb, dd) | N = 55 Age: 42 (range: 17–70) 69% female Migraine (n = 31), “muscle tension” HA (n = 7), or combination of both (n = 10) Chron: 19 yrs Rec: Referred by GPs to neurologist; England | Medical treatment = prophylactic regimen using propranolol, clonidine, pizotifen, metaclopramide, Migraleve^®^, or Migril^®^: n = 25 as first treatment; n = 11 as second treatment Acupuncture (using classical Chinese points, ± electrical stimulation; minimum of 6 points needled per session): n = 23 as first treatment; n = 18 as second treatment No baseline period described; two 3-mo treatment periods; no follow-up Acute, but not preventive, med permitted during acupuncture treatment phase; acute physical treatments (ice, massage, etc.) OK | Patients’ assessment of treatment: appears to have been based on frequency, severity, duration, and other measures, though this is not certain; graded as “great improvement,” “moderate benefit,” “slight benefit,” or “no benefit” | This was designed as a crossover trial, but 12/23 patients (52%) starting on acupuncture refused to change to medical treatment, and 7/25 (28%) starting on medical treatment refused to change to acupuncture. We therefore present results from the first period, considered as a parallel-group trial. Patients’ assessment of treatment: At the end of the first treatment period, 6/23 patients (26%) treated with acupuncture reported “great improvement,” 2/23 (9%) “moderate improvement,” 3/23 (13%) “slight improvement,” and 12/23 (52%) “no benefit.” In the group receiving medical treatment, the corresponding figures were 3/25 (12%), 1/25 (4%), 2/25 (8%), and 19/25 (76%), No statistical analysis was described by the investigators. Our own analysis (X^2^) showed no significant difference between the two treatments. | Dropouts: 7 (13%); also, see immediately left on patients who refused to cross over to alternative treatment Not clear how patients’ assessments of treatment were related to data recorded in their daily HA records 7/48 patients included in the efficacy analysis had TTH only
Myers and Myers, 1995 | SPPG QS:2 (r, ndb, dd) | N = 20 Age: N/S 70% female Migraine, diagnosed by a physician; current HA “severe,” “very severe,” or “most severe ever” Chron: N/S Rec: N/S; U.S. | Normobaric oxygen (100% oxygen at 1 atmosphere of pressure): n = 10 Hyperbaric oxygen (100% oxygen at 2 atmospheres of pressure): n = 10 Patients treated for 40 min inside a hyperbaric chamber | HA severity: Patients graded HA severity before entering and on exiting hyperbaric chamber on 10-cm descriptor scale, on which the six descriptors were “none” “mild” “moderate,” “severe,” “very severe,” and “most severe ever”; investigators analyzed number of patients improving from one of the “severe” categories to “mild” or “none” | HA severity: All patients reported “severe,” “very severe,” or “most severe ever” pain upon entering the hyperbaric chamber. After the 40-min treatment, 9/10 patients (90%) in the hyperbaric group reported “mild” pain or “none”; 1/10 patients (10%) in the normobaric group had this response. The difference between the two groups was statistically significant (p<0.005). | Dropouts: 0 No “untoward effects” of treatment were reported by patients Treatment modalities used to treat single acute episode of HA
Parker, Tupling, and Pryor, 1978 | SPPG OS: 2 (r, ndb, dd) | N = 99 Age: 41 (range 12–55) 61% female Migraine; ≥ 4 attacks during 2-mo baseline period Chron: 19 yrs Rec: Recruited through the media; U.S. | Cervical mobilization (oscillation) by medical practitioner or physiotherapist (control condition): n = 28 Cervical manipulation by medical practitioner or physiotherapist: n = 27 Cervical manipulation by chiropractor: n = 30 2-mo baseline period (HA recording), followed by 2-mo treatment phase, followed by 2-mo post-treatment phase; no more than 2 treatments/wk permitted during treatment phase; 20-mo follow-up results (HA frequency only) reported in Parker, Pryor, and Tupling (1980) Patients’ usual drug regimens continued unchanged throughout trial | HA frequency: Mean number of HAs in pre-and post-treatment periods HA severity: Mean severity scale, pre- and post-treatment (VAS, not described) HA duration: Mean duration (hrs/attack), pre- and post-treatment Disability: Mean disability, pre- and post-treatment; scored on scale of 1–5 (usual activities not disrupted; activity possible, but restricted; able to do essentials, but in considerable discomfort; most activities impossible; had to remain in bed) | When all three treatment groups were considered together, post-treatment scores were significantly better than pre-treatment scores for HA frequency, severity, and disability, but not for duration. There were no significant differences in any outcomes between the two groups receiving cervical manipulation, considered together, and the group receiving mobilization therapy. When the group receiving chiropractic manipulation was compared with the other two treatment groups, considered together, there was a significant difference in favor of chiropractic manipulation for pain intensity; otherwise there were no significant differences. Comparison of chiropractic manipulation with the control treatment (mobilization) alone showed no significant differences between them. Mean HA frequency, pre- and post-treatment: Mobilization, 8.7 and 5.7; MD/PT manipulation, 11.4 and 9.9; chiropractic manipulation, 8.5 and 5.1 (no variance data or p-values reported). Follow-up of 73/85 (86%) patients at 20 months showed that HA frequency continued to fall in all three groups (Parker, Pryor, and Tupling, 1980). The mean HA frequency for months 18–20 was 4.9 in the mobilization group, 8.0 in the MD/PT manipulation group and 3.8 in the chiropractic manipulation group (no variance data or p-values reported). Mean HA severity, pre- and post-treatment: Mobilization, 5.3 and 4.5; MD/PT manipulation, 5.0 and 4.4; chiropractic manipulation, 4.9 and 2.8 (no variance data or p-values reported). No follow-up data were reported. | Dropouts: 14 (14%) Unable to calculate ES because no variance data reported
Sheftell, Rapoport, and Kudrow, 1989 | SPPG QS:2 (nr, db, dd) | N = 71 Age: N/S % female N/S Common migraine or combination HA Chron: N/S Rec: N/S; U.S. | Sham cranial electrotherapy stimulation (sham CES), plus either beta-blocker, amitriptyline, or placebo: n = N/S Cranial electrotherapy stimulation (CES), plus either beta-blocker, amitriptyline, or placebo: n = N/S 12-wk baseline period, followed by 12-wk treatment period; CES/sham CES administered for 15 min, 2x/day, for 12 wks; no information provided about concomitant administration of beta-blockers, amitriptyline, and placebo | Frequency of severe HAs: Mean number of severe HA days/12 wks | Limited results were reported only for the group receiving active CES, so it was impossible to compare the effects of CES and sham CES. Investigators reported only that among patients receiving active CES, only those also taking beta-blockers showed a significant reduction in the frequency of severe HAs compared to baseline or to patients taking placebo (p<0.05 for both comparisons). Investigators concluded that CES may enhance the prophylactic effect of beta-blockers, but that further investigation is needed. | Dropouts: 13 (18%) Abstract providing very limited information; no comparison of CES and sham CES possible
Solomon and Guglielmo, 1985 | SPPG QS:2 (r, ndb, dd) | N = 62 Age: N/S % female N/S Migraine (n = 21), muscle contraction HA (n = 33), or both (n = 8); duration of current HA < half of typical HA at time of treatment Chron: N/S Rec: Patients presented with acute HA at hospital HA unit; U.S. | Placebo transcutaneous electrical nerve stimulation (TENS) = electrodes in place without electrical stimulation: overall n = 22; migraine n = N/S; mixed HA n = N/S Subliminal TENS = TENS at a level Just below the patient’s ability to experience the tingling stimuli: overall n = 18; migraine n = N/S; mixed HA n = N/S Perceived TENS = TENS at a level Just above the patient’s ability to experience the tingling stimuli: overall n = 18; migraine n = 6; mixed HA n = 1 Patients presented at HA clinic with acute HA underway; TENS (placebo, subliminal, or perceived) applied for 15 min Patients who had taken acute med within 24 hrs before presenting for treatment were excluded | HA severity: Patients graded HA severity on scale of 1–10 before and after treatment, with 10 being the most excruciating pain conceivable; investigators analyzed the % of patients in each treatment group whose HA severity was reduced by ≥ 2 points after treatment | HA severity: Treatment success was defined as a reduction in HA severity of ≥ 2 pts on a 10-pt scale. Very limited results were reported for migraine and mixed HA patients. 4/7 (57%) of these patients who were treated with perceived TENS achieved success, as did 7/20 (35%) treated with subliminal TENS or placebo (investigators did not report separate results for these two groups). When analyzed for each HA type, the degree of improvement reported with perceived TENS was not significantly greater than that reported with subliminal TENS or with placebo (no p-value reported). | Dropouts: 4 (6%), including 2 patients with migraine; no mixed HA dropouts Treatment modalities used to treat single acute episode of HA Definition of clinical “success” used does not meet our ≥ 50% improvement criterion
Vincent, 1989 | SPPG OS: 2 (r, ndb, dd) | N = 32 Age: 37 90% female Classical or common migraine; ≥ 2 full days of HA/mo Chron: 20 yrs Rec: Referred by neurologists or recruited from British Migraine Assoc; England | Placebo = sham acupuncture (light, surface needling at nonclassical points): n = 15 Acupuncture (eight classical points used in each treatment): n = 15 4-wk baseline period (HA recording), followed by 6-wk treatment period (one treatment/wk); follow-ups at 6 wks, 4 mos and 1 yr No preventive med permitted; acute med OK | Pain intensity: reported as mean total weekly pain scores (patients graded HA pain 4x1day on a 6-pt scale); mean number of pain-free days and peak HA intensity per week were also reported | Pain intensity was reduced to a significantly greater degree in the true acupuncture group than in the sham acupuncture group (p<0.03). Total mean weekly pain scores in the acupuncture group were 27.8 during the baseline period, 18.8 post-treatment (a 32% reduction from baseline), and 15.7 at 6-wk follow-up (a 44% reduction). In the sham acupuncture group, the corresponding scores were 27.2, 27.9 (a 3% increase), and 23.6 (a 13% reduction). 26/30 patients completing the trial (87%) were followed up at 1 year. Total mean weekly pain scores continued to improve in the true acupuncture group (n = 12) and were significantly lower than in the sham acupuncture group (n = 14): scores were 8.0 vs. 25.1, respectively (p<0.05). However, when the mean scores were adjusted for dropouts (by carrying forward scores for the 6-wk follow-up period), the difference between the two groups was not significant. Both treatments increased the mean number of pain-free days per week and decreased mean peak pain scores per week, but there was no significant difference between the two groups for these outcomes. | Dropouts: 2 (6%) before completing treatment; 4 more before 1-yr follow-up Unable to calculate ES, because no variance data reported
Wittchen, 1983 | SPPG QS: 2 (r, ndb, dd) | N = 30 Age: 39 (range: 24–53) 77% female Common or classical migraine (n = 21), mixed migraine + TTH (n = 7), or cluster (n = 2) (all Ad Hoc) Chron: 57%> 10 yrs Rec: Referred by GP or specialist; Germany | Wait-list control (HA monitoring only; patients seen by psychologist 1x/mo to monitor their recordings and motivate them to continue): n = 10 Acupuncture therapy (10 sessions over 8 wks, using classical Chinese points): n = 10 Psychological therapy (Aimed at training patients to observe, experience, and change critical physiological sensations associated with the occurrence of migraine attacks; patients treated in groups of 3–5; six 90-min sessions biweekly + four sessions 1x/wk; treatment administered in three phases [instruction, training, practice in relax. & self-coping skills]): n = 10 4-wk baseline period, followed by an 8-wk treatment period; follow-up at 4 and 8 wks Acute med permitted, but all patients encouraged to reduce their intake | HA frequency: Mean number of HA days/mo HA intensity: Mean weekly intensity score; patients graded attacks on a scale of 1–5 (slight, moderate, relatively severe, severe, unbearable) Frequency of disabling HAs: Mean number of days/wk with severe performance impairments | Both active treatments significantly reduced HA frequency and intensity from pre- to post-treatment (p < 0.05, each group, each outcome); patients in the wait-list group were not significantly improved (no p- value reported). Investigators did not report the results of any between-group comparisons for these outcomes. Similar results (and more data) were reported on pre- to post-treatment changes in the frequency of disabling HAs. In the psychological therapy group, the mean number of days/wk with severe performance impairments (± SD) was reduced from 2.4 (± 3.2) pre- treatment to 1.7 (± 1.8) post-treatment; in the acupuncture group, the reduction was from 3.4 (± 2.0) to 1.6 (± 2.0); and in the wait-list group, from 3.5 (± 5.0) to 3.0 (± 3.7). Investigators did not report the results of any between-group comparisons for this outcome. | Dropouts: 0 2/30 patients had cluster HA Patients referred for trial because of history of severe, long-term HAs

* Key: AE = adverse event; Assoc = Association; CES = cranial electrotherapy stimulation; Chron = chronicity; cm = centimeter; CrOv = cross-over; db = double-blind; dd = dropouts described; dept = department; ES = effect size; GP = general practitioner; HA = headache; IHS = International Headache Society; MD = medical doctor; med = medication; mg = milligram; min = minute or minutes; mo = month; mos = months; N or n = number of patients; ndb = not double-blind; neuro = neurology; nr = not randomized; N/S = not specified; PT = physiotherapist; QS = quality score; r = randomized; Rec = recruitment setting; SD = standard deviation; SPPG = single-period, parallel-group; TENS = transcutaneous electrical nerve stimulation; TTH = tension-type headache; VAS = visual analog scale; wk = week; wks = weeks; w/ = with; w/o = without; yr = year; yrs = years

** Quality score numbers: One point (for a total of five) is allocated for meeting (or subtracted for failing to meet) the following criteria: randomized (gains 1 pt if trial is described as such); randomized+ (gains 1 point if method of randomization is described); randomized − (loses 1 point if method of randomization is inadequate); double-blind (gains 1 point if trial is described as such); double-blind+ (gains 1 point if trial provides adequate description of double-blinding);double-blind − (loses 1 point if method of double-blinding is inadequate); dropouts described (gains 1 point if dropouts/withdrawals are described)

Evidence Table 4 Efficacy of Physical Treatments^*^

Study | Treatment | # Imprv’d/N (%)^**^ | Mean Values | | | | OC Measure | Effect Size (ES), Odds Ratio (OR), or p-value
Study | Treatment | # Imprv’d/N (%)^**^ | N | Before Treatment | After Treatment | % Improvement | OC Measure | Effect Size (ES), Odds Ratio (OR), or p-value
ACUPUNCTURE
Vs. no treatment (wait-list)
Wittchen, 1983 | Wait-list control | - | 10 | 3.5 | 3.0 | 0.14 | Freq of disabling HAs | ES, acu vs. WL: 0.31 (−0.57 to 1.2)
Wittchen, 1983 | Acupuncture | - | 10 | 3.4 | 1.6 | 0.53 | Freq of disabling HAs | ES, acu vs. WL: 0.31 (−0.57 to 1.2)
Vs. placebo (sham physical) treatments
Ceccherelli, Ambrosio, Avila, et al., 1987 | Placebo (sham acupuncture) | 5/15 (33%) | 15 | - | - | - | PI | OR, acu vs. plac: 12.9 (2.07 to 79.7)
Ceccherelli, Ambrosio, Avila, et al., 1987 | Acupuncture | 13/15 (87%) | 15 | - | - | - | | OR, acu vs. plac: 12.9 (2.07 to 79.7)
Dowson, Lewith, and Machin, 1985 | Placebo (sham TENS) | 6/23 (26%) | 23 | - | - | - | HF | OR, acu vs. plac: 1.33 (0.381 to 4.67)
Dowson, Lewith, and Machin, 1985 | Acupuncture | 8/25 (32%) | 25 | - | - | - | | OR, acu vs. plac: 1.33 (0.381 to 4.67)
Vincent, 1989 | Placebo (sham acupuncture) | - | 15 | 27.2 | 23.6 | 0.13 | PI | Unable to calculate ES (no variance data reported); p < 0.03 (acu better)
Vincent, 1989 | Acupuncture | - | 15 | 27.8 | 15.7 | 0.44 | | Unable to calculate ES (no variance data reported); p < 0.03 (acu better)
Vs. behavioral treatments
Wittchen, 1983 | Psychological therapy | - | 10 | 2.4 | 1.7 | 0.29 | Freq of disabling HAs | ES, acu vs. psych: 0.02 (−0.85 to 0.90)
Wittchen, 1983 | Acupuncture | - | 10 | 3.4 | 1.6 | 0.53 | Freq of disabling HAs | ES, acu vs. psych: 0.02 (−0.85 to 0.90)
Vs. pharmacological treatments
Hesse, Møgelvang, and Simonsen, 1994 | Metoprolol + placebo (sham acupuncture) | - | 39 | - | - | - | HF | Diff between two treatments n.s. (p>O.20)
Hesse, Møgelvang, and Simonsen, 1994 | Placebo tablets + acupuncture | - | 38 | - | - | - | HF | Diff between two treatments n.s. (p>O.20)
Loh, Nathan, Schott, et aI., 1984 | Medical treatment | 3/25 (12%) | 25 | - | - | - | HI | OR, acu vs. med: 2.58 (0.565 to 11.8)
Loh, Nathan, Schott, et aI., 1984 | Acupuncture | 6/23 (26%) | 23 | - | - | - | | OR, acu vs. med: 2.58 (0.565 to 11.8)
OTHER PHYSICAL TREATMENTS
Forsell, Kirveskari, and Kangasniemi, 1985 | Placebo (sham occlusal adjustment) | - | 17 | - | Mean reduction of 1.0 attack/mo | - | HF | Unable to calculate ES (no variance data reported)
Migraine-only | Occlusal adjustment | - | 18 | - | Mean reduction of 2.0 attacks/mo | - | | Unable to calculate ES (no variance data reported)
Forsell, Kirveskari, and Kangasniemi, 1985 | Placebo (sham occlusal adjustment) | - | 10 | - | Mean reduction of 3.2 attacks/mo | - | HF | Unable to calculate ES (no variance data reported)
Mixed migraine + TTH | Occlusal adjustment | - | 10 | - | Mean reduction of 4.4 attacks/mo | -
Myers and Myers, 1995 | Normobaric oxygen (control) | 1/10 (10%) | 10 | - | - | - | PI | OR, hyper vs. normo: 75.4 (4.43 to 1283)
Myers and Myers, 1995 | Hyperbaric oxygen | 9/10 (90%) | 10 | - | - | - | | OR, hyper vs. normo: 75.4 (4.43 to 1283)
Parker, Tupling, and Pryor, 1978 | Cervical mobilization by MD or physiotherapist (control) | - | 28 | 8.7 | 5.7 | 0.34 | HF | Unable to calculate ES (no variance data reported)
Parker, Tupling, and Pryor, 1978 | Cervical manipulation by MD or physiotherapist | - | 27 | 11.4 | 9.9 | 0.13
Parker, Tupling, and Pryor, 1978 | Cervical manipulation by chiropractor | - | 30 | 8.5 | 5.1 | 0.40
Sheftell, Rapoport, and Kudrow, 1989 | Placebo (sham CES) | - | - | - | - | - | HF | No usable data reported
Sheftell, Rapoport, and Kudrow, 1989 | CES | - | - | - | - | - | | No usable data reported
Solomon and Guglielmo, 1985 | Placebo (sham TENS) Subliminal TENS | 7/20 (35%) (plac + sublim combined) | 20 (combined) | - | - | - | PI | Did not calculate OR (def of “success” did not meet ≥ 50% improvement criterion)
Solomon and Guglielmo, 1985 | Perceived TENS | 4/7 (57%) | 7 | - | - | - | | Did not calculate OR (def of “success” did not meet ≥ 50% improvement criterion)

* Key: acu = acupuncture; CES = cranial electrotherapy stimulation; def = definition; diff = difference; ES = effect size; Freq = frequency; HA = headache; HF = headache frequency; HI = headache index; hyper = hyperbaric; Imprv’d = improved; MD = medical doctor; med = medication; mo = month or months; N or n = number of patients; normo = normobaric; n.s. = not (statistically) significant; OC = outcome; OR = odds ratio; PI = pain intensity; plac = placebo; psych = psychological treatment; sublim = subliminal; TENS = transcutaneous electrical nerve stimulation; TTH = tension-type headache; WL = wait-list

** The “# Imprv’d/N (%)” and “N (Mean Value)” may occasionally differ because the efficacy data for each may have been derived at different times in the study (patients may have dropped out, thus reducing the number).