# Therapies Included in/Excluded from Meta-Analysis

Study | Therapies Included in Meta-analysis^1^ | | | | | | | | Therapies Excluded from Meta-analysis
Study | Control | Placebo | RLX | TBF | TBF+RLX | EMG BF | Cog. | TBF+Cog. | Therapies Excluded from Meta-analysis
Barrios, 1980 | | | ✓ | | ✓ | | ✓
Bild and Adams, 1980 | ✓ | | | | | ✓ | | | BVP BF
Blanchard, Appelbaum, Nicholson, et al., 1990 | ✓ | | | | ✓^2^ | | | ✓^2^
Blanchard, Appelbaum, Radnitz, et al., 1990 | ✓ | ✓ | | | ✓ | | | ✓
Blanchard, Nicholson, Radnitz, et al., 1991 | ✓ | | | | ✓^3^ ✓^4^
Blanchard, Theobald, Williamson, et al., 1978 | ✓ | | ✓ | | ✓
Brown, 1984 | | ✓ | ✓ | | | | | | RLX (stimulus therapy)
Daly, Donn, Galliher, et al., 1983 | | | ✓ | | ✓ | ✓
Gauthier, Lacroix, Côté, et al., 1985 | ✓ | | | ✓ | | | | | BVP BF
Kewman and Roberts, 1980 | ✓ | | | ✓ | | | | | TBF to decrease temperature
Lake, Rainey, and Papsdorf, 1979 | ✓ | | | | ✓ | ✓ | | ✓
McGrady, Wauquier, McNeil, et al. | | ✓ | | | ✓^5^
Mullinix, Norton, Hack, et al., 1978 | | ✓ | | ✓
Nicholson and Blanchard, 1993 | ✓ | | | | | | | ✓
Richardson and McGrath, 1989 | ✓ | | | | | | ✓^6^ ✓^7^
Sorbi and Tellegen, 1984 | | | | | | | ✓ | ✓
Sorbi and Tellegen, 1986 | | | ✓ | | | | ✓
Wittchen, 1983 | ✓ | | | | | | ✓ | | Acupuncture

1 Abbreviations: AT = autogenic; beh. = behavioral; BF = biofeedback; BVP = blood volume pulse; cog. = cognitive; EMG = electromyographic; HCl = hydrogen chloride; PMR = progressive muscle relaxation; RLX = relaxation; TBF = thermal biofeedback

2 Home-based

3 With home practice

4 Without home practice

5 Contained EMG BF component, but classified as TBF + RLX because EMG BF component had fewer sessions

6 Minimal-therapist treatment

7 Clinic-based treatment

Studies Excluded from Meta-analysis
Study | Therapies
Anderson, Basker, and Dalton, 1975 | Hypnotherapy Drug (prochlorperazine [Stemetil^®^])
Andrasik, Blanchard, Neff, et al., 1984 | TBF or RLX (regular contact) TBF or RLX (booster contact)
Andreychuk and Skriver, 1975 | Hypnotherapy (self-hypnosis) TBF+RLX BF for alpha enhancement
Blanchard, Andrasik, Appelbaum, et al., 1985 | TBF + RLX (home-based) TBF + RLX (clinic-based)
Friedman and Taub, 1984 | Control RLX Hypnosis (4 treatments: high/low susceptibility with/without thermal imagery) TBF + RLX
Gauthier, Côté, and French, 1994 | TBF (without home practice) TBF (with home practice)
Holroyd, France, Cordingley, et al., 1995 | TBF+RLX Drug + beh. (propranolol HCI + TBF + RLX)
Holroyd, Holm, Hursey, et al., 1988 | TBF + RLX (home-based) Drug + beh. (ergotamine tartrate + compliance training) (home-based)
Ilacqua, 1994 | Control Guided imagery Guided imagery + TBF TBF + RLX
Janssen and Neutgens, 1986 | RLX (AT phrases) RLX(PMR)
Jurish, Blanchard, Andrasik, et al., 1983 | TBF + RLX (home-based) TBF + RLX (clinic-based)
Lacroix, Clarke, Bock, et al., 1983 | RLX TBF EMGBF
Machado and Gómez de Machado, 1985 | Control RLX TBF + RLX
Mathew, 1981 | Control (abortive ergotamine + analgesics) TBF + RLX + EMG BF 3 drug-only (propranolol, amitriptyline, propranolol + amitriptyline) 3 drug + beh. (propranolol + above BF mix, amitriptyline + above BF mix, propranolol + amitriptyline + above BF mix)
Mitchell and Mitchell, 1971 (Study 1) | Control RLX RLX + Cog. (combined desensitization)
Mitchell and Mitchell, 1971 (Study 2) | Control RLX + Cog. (systematic desensitization) Cog. (combined desensitization with no previous drug treatment) Cog. (combined desensitization with previous drug treatment)
Passchier, van der Helm-Hylkema, and Orlebeke, 1985 | Control Cog. + RLX Cog. + RLX + TBF Cog. + RLX + BVP BF
Penzien, Johnson, Carpenter, et al., 1990 | TBF + RLX + Cog. Drug (propranolol [Inderal^®^ LA])
Reading, 1984 | Placebo TBF Skin conductance BF EMG BF
Sargent, Solbach, Coyne, et al., 1986 | Control RLX TBF EMG BF
Sovak, Kunzel, Sternbach, et al., 1981 | TBF+ RLX Drug (propranolol + analgesics)

1 Abbreviations: AT = autogenic; beh. = behavioral; BF = biofeedback; BVP = blood volume pulse; cog. = cognitive; EMG = electromyographic; HCl = hydrogen chloride; PMR = progressive muscle relaxation; RLX = relaxation; TBF = thermal biofeedback

2 Home-based

3 With home practice

4 Without home practice

5 Contained EMG BF component, but classified as TBF + RLX because EMG BF component had fewer sessions

6 Minimal-therapist treatment

7 Clinic-based treatment