# Included Articles

Articles on behavioral treatments passing the title-and-abstract screen and included in this report

1 | Anderson, Basker, and Dalton, 1975
2 | Andrasik, Blanchard, Neff, et al., 1984
3 | Andreychuk and Skriver, 1975
4 | Barrios, 1980
5 | Bild and Adams, 1980
6 | Blanchard, Andrasik, Appelbaum, et al., 1985 Blanchard, Appelbaum, Guarnieri, et al., 1988 - Study reporting 1- and 2-yr follow-up data on patients from above trial
7 | Blanchard, Appelbaum, Nicholson, et al., 1990
8 | Blanchard, Appelbaum, Radnitz, et al., 1990
9 | Blanchard, Nicholson, Radnitz, et al., 1991
10 | Blanchard, Theobald, Williamson, et al., 1978 Silver, Blanchard, Williamson, et al., 1979 – One-year follow-up study of patients from above trial
11 | Brown, 1984
12 | Daly, Donn, Galliher, et al., 1983 Daly, Zimmerman, Donn, et al., 1985 – One-year follow-up study of patients from above trial
13 | Friedman and Taub, 1984
14 | Gauthier, Côté, and French, 1994
15 | Gauthier, Lacroix, Côté, et al., 1985
16 | Holroyd, France, Cordingley, et al., 1995
17 | Holroyd, Holm, Hursey, et al., 1988 Holroyd, Holm, Penzien, et al., 1989 – Three- year follow-up study of the 21 patients successfully treated (achieved ≥ 50% reduction in HA index) in above trial
18 | Ilacqua, 1994
19 | Janssen and Neutgens, 1986
20 | Jurish, Blanchard, Andrasik, et al., 1983
21 | Kewman and Roberts, 1980
22 | Lacroix, Clarke, Bock, et al., 1983
23 | Lake, Rainey, and Papsdorf, 1979
24 | Machado and Gómez de Machado, 1985
25 | Mathew, 1981
26 | McGrady, Wauquier, McNeil, et al., 1994
27 | Mitchell and Mitchell, 1971 - Study 1
28 | Mitchell and Mitchell, 1971 - Study 2
29 | Mullinix, Norton, Hack, et al., 1978
30 | Nicholson and Blanchard, 1993
31 | Passchier, van der Helm-Hylkema, and Orlebeke, 1985
32 | Penzien, Johnson, Carpenter, et al., 1990
33 | Reading, 1984
34 | Richardson and McGrath, 1989
35 | Sargent, Solbach, Coyne, et al., 1986 Solbach, Sargent, and Coyne, 1984 – Study of subset of patients with menstrual migraine from above trial
36 | Sorbi and Tellegen, 1984
37 | Sorbi and Tellegen, 1986 Sorbi, Tellegen, and Du Long, 1989 – Three- year follow-up study of patients from above trial
38 | Sovak, Kunzel, Sternbach, et al., 1981
39 | Wittchen, 1983