# Excluded Articles

Articles on behavioral treatments passing the title-and-abstract screen but excluded from consideration in this report

| Reference | Disposition
1 | Birbaumer, Gerber, Miltner, et al., 1984 | Interventions: Blood volume pulse (BVP) biofeedback (two treatment groups)
2 | Birbaumer and Haag, 1982 | Interventions: Included treatment compared with two cognitive-behavioral treatments that we would have grouped together (since we excluded BVP, we would have had no comparison group)
3 | Blanchard, Kim, Hermann, et al., 1994 | Primary focus of trial inappropriate: Studied mechanism by which thermal biofeedback training succeeds or fails, i.e., examined effect of patients’ “belief in success” on headache reduction
4 | Claghorn, Mathew, Largen, et al., 1981 | Interventions: Biofeedback training to decrease skin temperature
5 | Cohen, McArthur, and Rickles, 1980 | Interventions: Biofeedback training for vasoconstriction of temporal scalp arteries; electromyographic (EMG) biofeedback for forehead cooling; alpha brain wave feedback
6 | Drury, DeRisi, and Liberman, 1979 | Trial had fewer than five subjects
7 | Elmore and Tursky, 1981 | Interventions: BVP biofeedback
8 | Feuerstein and Adams, 1977 | Trial had fewer than five subjects Interventions: Cephalic vasomotor response biofeedback and EMG biofeedback for control of temporal artery
9 | Friar and Beatty, 1976 | Interventions: BVP biofeedback (temporal artery constriction)
10 | Gamble and Elder, 1983 | Trial had fewer than five subjects in each treatment group
11 | Gauthier, Bois, Allaire, et al., 1981 | Interventions: BVP biofeedback (temporal artery constriction, dilation); thermal biofeedback for decreasing skin temperature
12 | Gauthier, Doyon, Lacroix, et al., 1983 | Interventions: BVP biofeedback (temporal artery constriction, dilation)
13 | Gerhards, Rojahn, Boxan, et al., 1983 | Interventions: BVP biofeedback
14 | Haag and Gerber, 1987 | Does not report original research (abstract) Interventions: BVP biofeedback treatment compared with two cognitive-behavioral treatments that we would have grouped together (since we excluded BVP, we would have had no comparison group)
15 | Hart, 1984 | Results not reported separately for migraine
16 | James, Thorn, and Williams, 1993 | Results not reported separately for migraine
17 | Johansson and Ost, 1987 | Intervention: Not appropriate for this study because treatment was designed to test the efficacy of “generalization training” rather than that of thermal biofeedback itself
18 | Knapp, 1982 | One treatment group had fewer than five subjects
19 | Kohlenberg and Cahn, 1981 | Intervention: Treatment was “self-help” strategy involving no therapist contact
20 | Largen and Mathew, 1981 | Intervention: Thermal biofeedback (sham intervention) for decreasing skin temperature
21 | Largen, Mathew, Dobbins, et al, 1981 | Intervention: Thermal biofeedback for decreasing skin temperature
22 | Lisspers and Ost, 1990 | Interventions: BVP biofeedback (temporal artery constriction, dilation)
23 | Marcus, Scharff, and Turk, 1995 | Results not reported separately for migraine
24 | Martin, Nathan, Milech, et al., 1989 | Results not reported separately for migraine
25 | Price and Tursky, 1976 | No headache results provided
26 | Reich, 1989 | Interventions: Could not determine number of patients in the “greater-than” and “less-than 15 treatments” groups for the two interventions we might have been able to study (thermal biofeedback and “microelectrical” therapy); no defined timepoint for the outcome measured; encountered many problems interpreting data
27 | Solbach, Sargent, and Coyne, 1992 | Duplication of Solbach, Sargent, and Coyne, 1984
28 | Szekely, Botwin, Eidelman, et al., 1986 | Intervention: Person-centered insight therapy treatment
29 | Wauquier, McGrady, Aloe, et al., 1995 | Does not report what data patients measured or how headache outcomes were measured
30 | Williamson, Monguillot, Jarrell, et al., 1984 | Results not reported separately for migraine
31 | Winkler, Underwood, Fatovich, et al., 1989 | Results not reported separately for migraine