# Data Collection Form

Data Abstraction Form

First Author (last name):__________

ver 5.19.95

Pro-Cite no.:_______

Reviewer__________

Today’s date: __/__/____

EXCLUDE Why?

Are most or all of the patients in this study in the pediatric age group (0–17)?

No

Yes

-> STOP

State the inclusion criteria (headache diagnoses first)

Headache diagnosis:

Migraine

Tension-type

Cluster

mixed

other________

Diagnostic criteria:

IHS

Ad hoc

other

none/NS

State the exclusion criteria (headache diagnoses first)

Patient enrollment site (circle all that apply)

Primary Care Clinic

General Neurology Clinic

Headache Clinic

Not Stated

Emergency Clinic

Pain Clinic

Psychology clinic

Other__________

Design:

Unclear

Single-period parallel-group

Crossover

Matched pair (or paired)

For Cross-over design only-> Was there a significant carry-over effect? Yes No Not Stated

If “yes” then abstract “period one” data only as if the trial used a parallel group design.

Instrument to measure bias in pain research reports (Jadad 1996) | | Response | Score
1 | Was the study described as randomized (this includes the use of words such as randomly, random and randomization)? | Yes No | 1 0
la | If the method of generating the randomization sequence was described, was it adequate (table of random numbers, computer- generated, coin tossing, etc.) or inadequate (alternating, date of birth, hospital number, etc.)? | Not described/NA Adequate Inadequate | 0 1 −1
2 | Was the study described as double-blind? | Yes No | 1 0
2a | If the method of blinding was described, was it adequate (identical placebo, active placebo, etc.) or inadequate (comparison of tablet vs. injection with no double dummy)? | Not described/NA Adequate Inadequate | 0 1 −1
3 | Was there a description of withdrawals and drop-outs? | Yes No | 1 0

Describe the elements of the study design common to all groups (eg, 4 wk lead in, 12 wk treatment period)
Brief description of intervention | Details (including dose, duration, timing, etc.)
Intervention 1 (placebo or control or wait-list)
Intervention 2
Intervention 3
Intervention 4

Patient characteristics (overall: if figures are given by treatment groups, then calculate weighted average)

Age ______±______ or ________ (__ to __)

mean ± std dev median and (lower to upper range)

Female (%) _________

Chronicity of HIA d/o (x̄ years) _____

HA frequency (#HA/mo) ________

Patient characteristics describe:

pre-treatment (trial entry)

post-treatment (completion)

Adverse Event Frequency (%) | Overall | Intervention 1 | Intervention 2 | Intervention 3 | Intervention 4
Total entered study, n
Total completed study, n
Dropouts 2° S/E, (%)
Dropouts, total, (%)

Outcome measure Primary or secondary | Def”n (e.g. from 2 or 3 to 0 or 1) | How measured? (e.g. 4 pt scale) | When assessed? (2 hrs, 2 mo) | When were sx recorded? (daily, etc)

BEFORE/Period 1/single-period parallel-group design | Gp 1 | Gp2 | Gp3 | Gp4
Sample size
Mean
SD/VAR/SEM (circle one)
AFTER/Period 2
Sample size
Mean
SD/VAR/SEM (circle one)
BEFORE/AFTER comparisons
Mean
SD/VAR/SEM of difference (circle
Test statistic for diff
Degrees of freedom for test statistic
p-value of test statistic
Name of test statistic (e.g.; t, F, etc.)
BETWEEN GROUP COMPARISONS
Mean
SD/VAR/SEM of difference (circle
Test statistic for diff
Degrees of freedom for test statistic
p-value of test statistic
Name of test statistic (e.g.; t, F, etc.)
| F statistic | d.f. | p-value
OVERALL COMPARISON/ANOVA

Outcome measure Primary or secondary | Def” (e.g. from 2 or 3 to 0 or 1) | How measured? (e.g. 4 pt scale) | When assessed? (2 hrs, 2 mo) | When were sx recorded? (daily, etc)

| Outcomes (fill in dichotomous outcomes, categories, or ranges for groups as column headers) | | | | | Totals
| worst | | | | best
Treatments | N(%) | N(%) | N(%) | N(%) | N(%) | N (100%)
A
B
C
D

Outcome measure Primary or secondary | Def”n (e.g. from 2 or 3 to 0 or 1) | How measured? (e.g. 4 pt scale) | When assessed? (2 hrs, 2 mo) | When were sx recorded? (daily, etc)

| worst | | | | best | Totals
Treatments | N(%) | N(%) | N(%) | N(%) | N(%) | N (100%)
A
B
C
D