# Technical Review

## Introduction

Calculating the costs of chronic diseases poses many difficulties for the health services researcher. Individuals with diseases such as diabetes, hypertension, or lung disease often have comorbid conditions which require treatment and which produce costs of care that are hard to distinguish from the costs associated with the main condition in question. Chronic pain syndromes such as headache and low back pain are even more difficult to quantify in economic terms. Even with recent advances in the classification of headache syndromes, patients with chronic headaches remain difficult to diagnose, and data on the prevalence of the various types of headache are still lacking. Economic analysis of chronic headache is made more difficult by the fact that many sufferers treat their headaches with over-the-counter medications and do not seek medical care.

For the purposes of this report, “chronic headache” includes migraine, tension-type headache, cluster headache, and mixed migraine and tension-type headache. Most studies of the cost of care for headache, and of the clinical management of headache, pertain to migraine. This may be due, in part, to the investment of pharmaceutical companies in drugs to treat migraine, which is a relatively well-defined and prevalent headache syndrome.

Ideally, an analysis of the cost of headache would include direct medical and non-medical expenses, as well as indirect costs. Our search of the literature yielded information on rates of health care provider consultation, hospitalization, and use of the emergency department services. We also found some data on pharmaceutical use and the cost-effectiveness of non-pharmacological treatments. In addition, there is a small body of literature on work loss and absenteeism due to headache.

However, large gaps exist in the literature. We do not, for example, know the average number of health care provider visits it takes to reach a diagnosis of chronic headache, how many and what kinds of tests are performed to make a diagnosis, what kinds of treatment options patients are offered, or how many medications are tried before relief is obtained or the patient gives up treatment. We need to better understand why patients with chronic headache are admitted to the hospital and what is done for them while they are there. We also do not know all there is to know about the impact of chronic headache on work—whether chronic headache prevents people from obtaining or retaining jobs or has an effect on their ability to advance in their job. We must also determine from whose perspective the economic impact of headache should be viewed. Insurers, for example, may not have an interest in work loss or absenteeism. Employers may be concerned about medical costs and work loss but not the impact on family life or social role functioning.

Until these and other questions can be answered, it will remain difficult to estimate the aggregate economic burden of headache or to estimate the costs of headache for cost-effectiveness analysis or cost-benefit analysis. In the closing section of this report, we present a more detailed discussion of the information and analytical strategies required for a more comprehensive analysis of the cost of headache.

We have chosen not to review papers on the prevalence of chronic headache, as good summaries of this literature have already been published (Kroenke and Mangelsdorff, 1989; Linet, Celentano, and Stewart, 1991; Lipton, Stewart, Celentano, et al., 1992; Stang, Sternfeld, and Sidney, 1996; Stewart, Lipton and Liberman, 1996; Winnem, 1992).

## Methodology

This review is based on a comprehensive search of the literature involving multiple, parallel strategies. The primary strategy involved computerized searches of the MEDLINE, HealthStar, and CINAHL databases for relevant studies published between January 1966 and December 1996. The original search strategy (Appendix A) was designed to identify articles relating to the cost of care and the economic impact of chronic headache. We initially ran this search to capture articles published through December 1996 and entered into MEDLINE, HealthStar, or CINAHL before the end of January 1997. We later extended this search to identify articles that had been published before the end of 1996, but entered into the databases after January 1997. We also revised the original search by including the MeSH terms “drug utilization” and “drug utilization review” and the “utilization” subheading (used as a floating subheading) (Appendix B).

As part of the overall evidence report project, separate computerized searches of MEDLINE were performed to identify studies concerning the diagnosis and treatment of chronic headache and review articles on these topics, and reviewers of all this literature were instructed to be vigilant for studies appropriate for this report. We also reviewed a Cochrane Collaboration database of pain trials for relevant literature. Finally, a small number of papers were identified through a formal process of reviewing the reference sections of relevant articles (reviews and original research reports) and through recommendations from experts and reviewers. A total of 424 citations were identified and screened. Table 1 provides a detailed breakdown of these citations by source.

Table 1 Literature search yield broken down by source^*^

Source | Original cost search strategy | Original strategy, post-1/97 entry | Revised strategy (incorporating new terms) | Totals
Database:
MEDLINE | 247 | 17 | 76 | 340
Health Star | 30 | 5 | 6 | 41
CINAHL | 6 | 0 | 13 | 19
Subtotal: | | | | 400
Other sources:
Treatment search | | | | 11
Diagnostic search | | | | 4
Review article search | | | | 1
Cochrane database of pain trials | | | | 0
Other (peer reviewers, review article citations, etc.) | | | | 8
Subtotal: | | | | 24
Total: | | | | 424

* Totals given for each source exclude articles also identified through the sources listed above it or (in the case of the multiple searches of MEDLINE, HealthStar, and CINAHL) to the left of it in this table.

The titles and abstracts of the 424 citations identified through these means were then screened. Articles were included for further review if they were:

1. Published in English;
2. Full reports of original research (Le., not a letter, editorial, case report, review, or abstract);
3. About an adult (non-pediatric) subject population; and
4. About a subject population suffering from primary headache (Le., not traumatic, post-lumbar puncture, or other secondary headaches).

Of the 424 citations screened according to the above criteria, 127 (30%) were included for further review. We were not able to obtain a copy of one of these articles (Cull, Wells, and Miocevich, 1992). The remaining 126 were read in full and subjected to an additional review of their content and methods. In order to be included at this stage, articles were required to:

1. Meet the above screening criteria;
2. Contain material relevant to the economic impact of chronic headache on medical resource utilization or work loss;
3. Meet minimal methodological criteria related to the validity of cost or utilization measures.

Thirty-five of the 126 articles reviewed met these criteria. Reasons for excluding the remaining 91 articles are provided in Appendix C. Data from the included articles were abstracted onto specially designed data collection forms (Appendix D). Studies which addressed more than one measure of utilization were analyzed wherever applicable.

The studies reviewed in this report used a variety of methods for gathering cost and utilization data. In some cases, epidemiological methods were used to assess utilization in a defined population. Other studies used before-after measures to determine the impact of an intervention on utilization or cost outcomes. While there have been numerous methodological standards published for evaluating the quality of cost-effectiveness or other economic analyses of clinical practices (Drummond, Richardson, O’Brien, et al., 1997; Siegel, Weinstein, Russell, et al., 1996), we were not able to identify any widely accepted or particularly useful scales for grading the broad variety of studies included in this report; thus, we did not formally grade the quality of the evidence provided by the studies. We have, however, commented on the quality of this evidence in the text of the report and have also attempted to describe the potential biases of individual studies and the direction of these biases. In four cases, articles with major methodological flaws threatening the validity of the cost or utilization data reported were excluded from consideration; these cases are described in Appendix C.

## Results

### Utilization of Health Care Resources

#### Health Care Provider Consultation

A large percentage of people with chronic headache seek the advice of a health care provider at some point in their lives. Eight of the studies reviewed reported consultation rates which ranged between 56%–91 % for migraine headache (Clouse and Osterhaus, 1994; Edmeads, Findlay, Tugwell, et al., 1993; Green, 1977; Linet, Stewart, Celentano, et al., 1989; Osterhaus, Gutterman, and Plachetka, 1992; Rasmussen, Jensen, and Olesen, 1992; Stang and Osterhaus, 1993; van Roijen, Essink-Bot, Koopmanschap, et al., 1995). Consultation rates for tension-type headache were generally lower, ranging from 16% to 71 % (Edmeads, Findlay, Tugwell, et al., 1993; Rasmussen, Jensen, and Olesen, 1992). Health care provider consultation rates for all eight studies reviewed are provided in Table 2. The relevant studies are summarized in Evidence Table 1.

Table 2 Health care provider consultation rates for headache

Study | Setting | Headache type | Demographic group | Consultation rate^*^ | Time period
Clouse and Osterhaus, 1994 | managed care primary care | migraine | all | 90% | 18 mo
Osterhaus, Gutterman, and Plachetka, 1992 | specialty clinic | migraine | all | 91% | 12 mo
Mounstephen and Harrison, 1995 | employee | migraine | all | 58% 19.4% | lifetime 12 mo
Green, 1977 | community | migraine | female male | 74% 66% | lifetime
Linet, Stewart, Celentano, et al., 1989 | community | migraine | female male | 28% 15% | lifetime
Stang and Osterhaus, 1993 | community | migraine | female male | 85% 77% | lifetime
Edmeads, Findlay, Tugwell, et al., 1993 (interview survey) | community | migraine tension-type | all all | 81% 71% | lifetime
Edmeads, Findlay, Tugwell, et al., 1993 (prevalence study) | community | migraine tension-type | all all | 64% 45% | lifetime
Rasmussen, Jensen, and Olesen, 1992 | community | migraine tension-type | all all | 56% 16% | lifetime
van Roijen, Essink-Bot, Koopmanschap, et al., 1995 | community | migraine or migraine + tension-type | all | 70% | lifetime

* Consultation rate is the percentage of symptomatic patients seeking the care of a primary care or specialist health care provider in an office-based practice, not in an emergency department or inpatient setting.

The severity of headache appears to play a role in health care provider consultation. Rasmussen, Jensen, and Olesen (1992) reported that patients with more severe attacks were more likely to seek care from a provider. Patients interviewed by Edmeads, Findlay, Tugwell, et al. (1993) who had never consulted a physician about their headaches stated that their symptoms were not severe enough to warrant such a consultation and/or that they were able to treat their headaches satisfactorily with non-prescription medications.

Chronic headache sufferers who seek medical advice do not necessarily continue to consult a health care provider. Edmeads, Findlay, Tugwell, et al. (1993) found in an interview survey that of the 81 % of migraine sufferers who had sought care at any time previously, only 36% were receiving care at the time of the survey; similarly, of the 71 % of tension-type headache sufferers who had ever sought care, only 28% were still receiving care. Some respondents listed as their primary reasons for not continuing care the availability of non-prescription medications and the fact that they were not having headaches of sufficient frequency or severity to warrant continuing in care. More than 50%, however, said that they did not return because they were unhappy with their health care providers or had experienced negative side-effects with their medications.

As a group, patients with migraine have higher rates of health care provider consultation than does the general population. Clouse and Osterhaus (1994) reported the results of a study in which a sample of 1,336 migraineurs were matched with a comparison group of 1,336 non-migraineurs for age, sex, duration of enrollment, and subscriber/dependent status in a United Health Care Corporation-affiliated health plan. Migraineurs had much higher rates of resource utilization and costs in every category measured. In the 18-month study period, migraineurs made 2,616 migraine-related physician visits and 19,971 non-migraine-related physician visits; non-migraineurs made a total of 13,072 physician visits in the same time period.

Among migraineurs, a small number of patients have particularly high consultation rates. Osterhaus, Gutterman, and Plachetka (1992) reported that although most migraineurs in their study averaged 1–4 physician visits per year, 7.6% of the subjects made more than 12 visits per year to primary care and specialty physicians for the care of their headaches.

#### Predictors of Receiving a Headache Diagnosis

Community-based studies suggest that a large number of people who satisfy widely accepted diagnostic criteria for migraine or tension-type headache never receive a diagnosis of their condition from a physician. Celentano, Stewart, Lipton, et al. (1992) and Lipton and Stewart (1993) analyzed the results of a survey of the general U.S. population in which subjects were asked a series of questions, the answers to which would allow the researchers to classify the subjects’ headaches according to the International Headache Society (IHS) criteria for migraine or chronic tension-type headache (Headache Classification Committee of the International Headache Society, 1988). Celentano, Stewart, Lipton, et al. (1992) reported that only 29.7% of males and 41.6% of females meeting the IHS criteria for migraine reported having received a diagnosis of migraine from a physician.

Lipton and Stewart (1993) examined predictors associated with receiving a physician diagnosis of migraine in this same group of patients. The strongest predictor of physician diagnosis was household income. Among patients found to meet the IHS criteria for migraine, a physician diagnosis was 40% more likely for persons whose household incomes were $45,000 or more per year than for persons in households with an average income of less than $10,000 per year. Another strong predictor of physician diagnosis was female sex. Women were 40% more likely than men to be diagnosed with migraine. Increasing age was also a factor.

#### Use of the Emergency Department (ED) for the Treatment of Migraine

Studies providing data on the use of the ED for the treatment of chronic headache are summarized in Evidence Table 2. One of these studies (Osterhaus, Gutterman, and Plachetka, 1992) reported that a high percentage (48%) of migraine patients surveyed had visited the emergency department for treatment of an acute attack of migraine in the previous 12 months. Furthermore, 15% of the study’s subjects accounted for 60% of all emergency department visits. Patients for this study were recruited from a group of migraine patients who had previously participated in clinical trials of migraine medication. It is possible that this population suffers from more frequent and/or more severe headaches than do other migraineurs and, consequently, that they visit the ED more frequently. The other studies reviewed reported lower rates of ED use, ranging from 3%–20% of migraineurs over periods of time ranging from 6 months to lifetime (see Table 3).

Table 3 Emergency department (ED) use for acute headache among migraineurs

Study | Setting | Headache type | Demographic group | Patients seen in ED (%) | Time period
Clouse and Osterhaus, 1994 | managed care, primary care | migraine | all | 18% | 18 mo
Edmeads, Findlay, Tugwell, et al., 1993 | community | migraine | all | 14% | lifetime
Michel, Pariente, Duru, et al., 1996 | community | migraine | all | 5% | 6 mo
Osterhaus, Gutterman, and Plachetka, 1992 | specialty clinic | migraine | all | 48% | 12 mo
Celentano, Stewart, Lipton, et al., 1992 | community | migraine | male female | 13% 20% | lifetime
Linet, Stewart, Celentano, et al., 1989 | community | migraine | male female | 5% 3% | 12 mo

One study (Celentano, Stewart, Lipton, et al., 1992) reported that the probability of ED use among migraineurs varied according to whether patients used prescription medication, non-prescription medication, or no medication. Prescription drug users had the highest lifetime rates of ED utilization (33% for men and 27% for women), and non-prescription drug users the lowest (one-third of the prescription drug user rates). Those migraineurs using no medications reported intermediate rates of ED utilization (20% for men and 15% for women). The investigators were not able to identify whether the high rate of ED use among prescription drug users was due to the severity of the subjects’ headaches, medication failure, or side-effects associated with their medication.

The studies summarized in Table 3 all reported rates of ED use by migraineurs, but did not provide many details of how ED services were used. Two other studies provided slightly more information. Kaa, Carlson, and Osterhaus (1995) studied consecutive migraine patients presenting to the walk-in ED at the Group Health Cooperative Central Hospital in Seattle. Of 16,755 total patient visits to the ED, 323 (1.9%) were for migraine. These 323 visits were made by 152 patients; 36% of patients made repeat visits. Though the authors did not state the precise reasons these patients went to the ED for treatment of their headaches, they do report the most common symptoms given on presentation. Headache was reported by 98.8% of patients, nausea by 47.4%, photophobia by 31.6%, and vomiting by 28.2%. Most migraineurs (62.2%) had taken medication to treat their headaches before presenting at the ED (24%, over-the-counter analgesics; 19%, narcotic analgesics; 13%, ergots; and 12%, Midrin^®^). The median time spent in the ED was one hour, and no diagnostic tests were performed in 95% of visits. Most patients received meperidine injections with promethazine or hydroxyzine; antiemetics alone were given at 51.7% of visits; and antihistamines at 38.4% of visits. In 64% of ED visits for migraine, the encounter was completed with no arrangement for follow-up or referral; 34% of visits ended with instructions for the patient to follow-up with their primary care physician; at 2% of visits patients were referred to specialists; and one patient was admitted to the hospital.

Salomone, Thomas, Althoff, et al. (1994) reviewed the records of patients presenting to the ED at Truman Medical Center in Kansas City. Of 132,653 total ED visits, 2,540 (1.9%) were for headache, and of these, 13.3% were specifically for migraine. After verification of coding, the study population included 185 patients with 339 visits. Repeat visits were made by 39% of patients. Three or more visits were made by 21 patients, accounting for 42.5% of all visits. Only 1.5% of emergency department visits were described as being for “first” headache and 3.2% were for “worst” headache. Of the patients studied, 54.6% reported that they had not taken any medication before coming to the ED. Prophylactic medications were used by 17.3% of patients who made only one visit to the emergency department, 58.1 % of those who made two visits, and 76.2% of those who made three or more visits. At 19 visits, patients reported that their medications had been ineffective, and at eight visits they reported that they had run out of medication. Medication was administered in the ED in 82.3% of visits and provided complete or considerable relief in 64.5% of those cases.

#### Hospitalization

Hospitalization rates were reported in five of the papers reviewed (Table 4; see also Evidence Table 3). Between 6% and 11% of patients with migraine reported hospitalization for treatment of their headaches at some point in their lifetime (Clouse and Osterhaus, 1994; Michel, Pariente, Duru, et al., 1996; Osterhaus, Gutterman, and Plachetka, 1992; Stang and Osterhaus, 1993). Clouse and Osterhaus (1994) reported that migraineurs had overall hospitalization rates nearly twice as high as those in a non-migraine comparison group.

Table 4 Hospitalization rates for treatment of headache

Study | Headache type | Demographic group | Rate of hospitalization (for headache) | Time period
Clouse and Osterhaus, 1994 | migraine | all | 10.6% | 18 mo
Michel, Pariente, Duru, et al., 1996 | migraine | all | 7% | 6 mo
Osterhaus, Gutterman, and Plachetka, 1992 | migraine | all | 7.0% | 12 mo
Stang and Osterhaus, 1993 | migraine | female male | 8.4% 6.2% | lifetime
Rasmussen, Jensen, and Olesen, 1992 | migraine or tension-type | all | 2.0% | lifetime

### Pharmaceutical Use

The discussion below focuses on the types of medications used by headache sufferers and the patterns with which they are used, rather than on summary measures of the economic cost of pharmaceutical use. Data on the average wholesale price of drugs are readily available from other sources (Medical Economics Company, 1996).

Chronic headache sufferers have several options for the pharmacological treatment of their headaches: prescription versus non-prescription treatment and treatment for prevention versus treatment for the relief of acute episodes. Almost all headache sufferers report having used some sort of pharmaceutical agent to treat their headaches at some time. Overall rates of medication use are reported to be near 95% (Lipton and Stewart, 1993; Kryst and Scherl, 1994).

The studies reviewed for this section of the report are described in Evidence Table 4.

#### Prescription vs. Non-Prescription Drug Use

All the studies reviewed showed higher rates of non-prescription than prescription drug use (Table 5). Several clinical factors seem to be related to the use or non-use of prescription medications. Individuals experiencing severe headaches are more likely to consult a health care provider (Rasmussen, Jensen, and Olesen, 1992) and thus more likely to obtain prescription medication. Among patients with severe headache, those with migraine are more likely to use prescription drugs. Celentano, Stewart, Lipton, et al. (1992) found that, of a group of patients who reported “severe headache,” but who did not meet the IHS criteria for migraine according to a self-report questionnaire, 15.7% of men and 22.1 % of women reported prescription medication use; of patients with severe headache who did meet the diagnostic criteria for migraine, 28.3% of men and 40.1 % of women used prescription drugs. The same study found that patients with higher headache-related disability, more frequent attacks, headache associated with vomiting, and migraine with aura were all more likely to use prescription medications.

Table 5 Use of prescription and non-prescription drugs for headache

Study | Headache type | Demographic group | Patients using non-prescription drugs for headache^*^ | Patients using prescription drugs for headache^*^ | Time period
Celentano, Stewart, Lipton, et al., 1992 | severe headache (not migraine) | men | 74.6% | 15.7% | not specified (“current usual treatment”)
Celentano, Stewart, Lipton, et al., 1992 | severe headache (not migraine) | women | 62.5% | 22.1% | not specified (“current usual treatment”)
Celentano, Stewart, Lipton, et al., 1992 | migraine | men | - | 28.3% | not specified (“current usual treatment”)
Celentano, Stewart, Lipton, et al., 1992 | migraine | women | - | 40.1% | not specified (“current usual treatment”)
Clarke, MacMillan, Sondhi, et al., 1996 | migraine | all | 78% | 28% | 3 mo
Edmeads, Findlay, Tugwell, et al, 1993 | migraine tension-type | all | 91% 90% | 44% 24% | ever
Kryst and Scherl, 1994 † | severe headache (migrainous or non-migrainous) among patients using medications | 50% | 42.7% | 1 year
Kryst and Scherl, 1994 † | disabling headache (migrainous or non-migrainous) | 50% | 45.3% | -
Linet, Stewart, Celentano, et al. (1989) | migraine | men | | | 1 year
Linet, Stewart, Celentano, et al. (1989) | migraine | age 12–17 | - | 8.8% | 1 year
Linet, Stewart, Celentano, et al. (1989) | migraine | age 18–23 | - | 16.2% | 1 year
Linet, Stewart, Celentano, et al. (1989) | migraine | age 24–29 | - | 18.0% | 1 year
Linet, Stewart, Celentano, et al. (1989) | migraine | women | | | 1 year
Linet, Stewart, Celentano, et al. (1989) | migraine | age 12–17 | - | 10.9% | 1 year
Linet, Stewart, Celentano, et al. (1989) | migraine | age 18–29 | - | 16.8% | 1 year
Lipton and Stewart, 1993 | migraine | men women | 66.9% 56.8% | 28.3% 40.1% | not specified
Mounstephen and Harrison, 1995 | migraine | all | - | 10% | 1 year

* Percentages of non-prescription and prescription drug use represent either the type of medication used at the time of the study by the subject or the most frequently used type of medication over the lifetime of the subject depending upon the study.

† Data reported on all patients using some type of medication in the last year; 7.3% of respondents used both prescription and non-prescription medications to treat their headaches.

Some patient-centered factors may also influence the likelihood of the use of prescription medication. Use of prescription drugs appears to increase with age. In a survey of young headache sufferers, Linet, Stewart, Celentano, et al. (1989) found that the rate of prescription drug use doubled from 8.8% in boys 12 to 17 years old to 18% in men 24 to 29 years old. A similar pattern was noted among women. Celentano, Stewart, Lipton, et al. (1992) also found that the use of prescription medications was greater in older age groups, increasing from 26% among men under 30 years of age to 38.6% among men between the ages of 50 and 59. Prescription drug use was also found to be higher among women than men (Celentano, Stewart, Lipton, et al., 1992; Linet, Stewart, Celentano, et al., 1989; Lipton and Stewart, 1993).

Kryst and Scherl (1994) reported that respondents to the Kentucky Health Survey who said that their headaches interfered with their family life were more likely to use prescription medications. The same study found that the use of prescription medications was not related to income level or insurance coverage. Similarly, Celentano, Stewart, Lipton, et al. (1992) reported that migraineurs with incomes less than $20,000 per year were less likely, but not significantly so, to use prescription medications than those with higher incomes.

Celentano, Stewart, Lipton, et al. (1992) examined differences in medication use by race and reported that black migraineurs had a much lower rate of prescription drug use than whites: 14% versus 29% among men, and 30% versus 40% among women. However, blacks had a slightly higher rate of non-prescription drug use than whites: 71 % versus 67% among men, and 61% versus 57% among women. Black women were less likely than white women or women of other racial groups to use prescription medications or any medications at all.

A surprising number of patients with apparently troublesome headache symptoms do not use prescription drugs. Lipton and Stewart (1993) found in a survey that 43% of men and 34% of women with three or more headaches per week did not use prescription medication. Similarly, 61 % of men and 47% of women who reported moderate to severe disability due to headache did not use prescription medications. Kryst and Scherl (1994) found that 45.3% of subjects who described their headaches as disabling took only non-prescription medications.

In addition, it appears that many patients who try prescription medications do not continue to use them. Edmeads, Findlay, Tugwell, et al. (1993) found in their interview survey that 62% of headache sufferers who had seen a physician for the treatment of headache had been given a prescription. However, only 34% of these patients were still taking their prescription medication at the time of the survey. The reasons cited by patients for discontinuing their medication were as follows: 53% felt that they could get adequate relief with non-prescription medication; 26% experienced unwanted side-effects of their prescription medication, felt that the relief it provided was inadequate, or were concerned about taking a prescription medication; and 21 % stated that their headaches did not bother them, had resolved, or were of insufficient frequency or severity to require prescription medication. The same study reported that physicians recommended non-prescription medications for 50% of their patients and that 25% of these patients had discontinued taking their non-prescription medications.

#### Use of Preventive Medications

Patients with recurrent headache may be treated with acute or preventive medication or with some combination of the two. It appears, however, that preventive drug treatments are used by only a small percentage of patients (Table 6). It is unclear whether the patients in these studies had never been offered preventive therapy or had tried it and found it ineffective.

Table 6 Use of preventive medications for headache

Study | Headache type | Patients reporting use of preventive medications for headache | Drug
Clarke, MacMillan, Sondhi, et al., 1996 | migraine | 5% | propranolol, pizotifen
Edmeads, Findlay, Tugwell, et al., 1993 | migraine tension-type | 5% 2% | not specified not specified
Mounstephen and Harrison, 1995 | migraine | 13% | not specified
Rasmussen, Jensen, and Olesen, 1992 | migraine | 4% 3% | beta blockers clonidine

#### Frequency of Medication Use for Treatment of Acute Headache

Headache sufferers who use medications (prescription or non-prescription) to treat acute episodes of headache appear to use these medications intensively. Edmeads, Findlay, Tugwell, et al. (1993) reported that the migraine and tension-type headache sufferers in their prevalence study used medication an average of three times per week. Medications were used more than once per week by 20% of migraine sufferers and 17% of tension headache sufferers. Micieli, Frediani, Cavallini, et al. (1995) reported that 5.3% of their study population consumed more than one analgesic compound per day for headache relief. Additionally, 12.7% reported daily use of analgesics, 46.6% reported weekly use, 28% reported monthly use, and 7.5 % denied using any analgesics. Chronic tension-type headache patients had a greater tendency toward daily use.

Von Korff, Galer, and Stang (1995) reported a detailed study of the frequency of medication use among patients treated for headache in a managed care setting. Subjects were recruited from patients making visits to primary care providers at Group Health of Puget Sound. Headache diagnoses among the population studied included migraine or migraine plus tension-type headache (57.4%), tension-type headache only (30.1 %), and . other headache diagnoses (12.5%). Frequent medication use (defined as more than 14 days per month) was observed in 18.4% of patients using prescription drugs and 20.1 % using non-prescription drugs. The authors found that non-prescription medications were slightly more frequently used at the baseline interview than in the 1-year and 2-year follow-up periods. The overall use of prescription medications declined between the baseline and 1-year follow-up and remained stable between years 1 and 2. In a multivariable model, increasing age and higher frequency of headaches were found to be independent predictors of frequent analgesic use.

Ottervanger, Valkenburg, Grobbee, et al. (1996) examined the use of sumatriptan by patients of general practitioners in the Netherlands. Most of the 952 patients in the study (75%) took sumatriptan 1–10 times per month. However, 4% of patients took sumatriptan daily or more than 10 times per week and were considered to be overusers. Most overusers were men, and most of them reported a poor efficacy for sumatriptan. Frequency of use of sumatriptan was not related to age. Gaist, Hallas, Sindrup, et al. (1996) described the use of sumatriptan in Denmark using a population-based prescription database. Of 2,878 patients receiving sumatriptan, 1,283 (45%) redeemed only one prescription during the 27-month study period. Twenty percent of the total sumatriptan use was accounted for by the heaviest 1% of users. Heavy sumatriptan users were also the highest consumers of opiates and ergot alkaloids.

The heavy utilization of pharmaceuticals by chronic headache sufferers can also be stated in economic terms. Clouse and Osterhaus (1994) compared the medical and pharmacy claims of 1,336 migraine patients and 1,336 non-migraine patients receiving care at a United Health Care Corporation affiliated health plan. In the 18-month study period, the migraine group averaged 21 pharmacy claims per patient, whereas the non-migraine group averaged 7 claims per patient. The health plan paid out $495,542 in pharmacy claims for the migraine group and $177,774 for the non-migraine group.

#### Effect of Sumatriptan on Drug and Health Care Resources Utilization

The majority of studies reviewed for this report were performed before the introduction of the anti-migraine drug sumatriptan in 1993. The routine use of sumatriptan in clinical practice may have a significant impact on practice patterns and the utilization of health care resources, but the precise nature and magnitude of this impact are as of yet uncertain.

Litaker, Solomon, and Genzen (1996) compared the utilization of services and costs of care in a group of 104 migraineurs for 18 months before and after they began regular use of sumatriptan. The mean number of physician visits for migraine (excluding initial consultation) decreased significantly from two visits before sumatriptan to one visit after its introduction. The authors measured the costs of care in terms of both professional and institutional costs (the cost of sumatriptan was not included in the analysis) and concluded that there was a 40% reduction on overall costs after the introduction of sumatriptan.

Cohen, Beall, Miller, et al. (1996) examined the effect of sumatriptan use on resource utilization in a group-model health maintenance organization. Subjects were allowed to self-treat an unlimited number of migraine attacks with subcutaneous sumatriptan in a 12-month period. The authors compared the number of physician visits, emergency department visits, diagnostic imaging studies, and prescription services in the 12 months preceding the study and the 6 months following the start of sumatriptan treatment. The number of physician and emergency department visits decreased significantly, while the number of prescription services increased significantly. The number of diagnostic imaging studies performed was low during the pre-treatment period and remained unchanged after the introduction of sumatriptan.

Although some types of resource use and associated costs may decrease with wider use of sumatriptan, there is a potential for increases in resource use and costs in other areas. It is conceivable, for example, that the availability of sumatriptan in EDs may encourage more patients with migraine to seek treatment at these facilities for acute episodes of headache. Similarly, publicity about sumatriptan may encourage more migraineurs to consult health care providers to obtain a prescription. Further research will be needed to determine the precise impact of sumatriptan on practice patterns, resource utilization, and costs of care.

### Non-Pharmacological Therapy

The literature review identified three studies of the cost-effectiveness of non-pharmacological treatments for chronic headache (Attanasio, Andrasik, and Blanchard, 1987; Blanchard, Andrasik, Appelbaum, et al., 1985; Blanchard, Jaccard, Andrasik, et al., 1985). These studies are summarized in Evidence Table 5. All three were conducted by the same research group.

Blanchard, Jaccard, Andrasik, et al. (1985) described a very large reduction in medical costs among patients undergoing relaxation and biofeedback training. Costs considered included medication, visits to family physicians and neurologists, hospital costs, and costs for alternative treatments such as acupuncture and chiropractic. A total of 73 patients were randomized into one of three treatment arms, and pre- and post-treatment cost data were collected and compared. The authors reported a reduction in medical expenses from $955 in the 2 years pre-treatment to $52 in the 2 years post-treatment.

There were a number of methodological problems with this study. The investigators did not describe the patient population, the method in which patients were recruited, or the inclusion/exclusion criteria used. Also, medical cost data were obtained from 45 of 73 patients in the pre-treatment study group and from 20 of 73 in the post-treatment group, but it was unclear how many (if any) patients provided both pre- and post-treatment data. Finally, all cost data were self-reported based on patients' personal expense and tax records, introducing possible recall bias. The authors acknowledged the limitations of the study, but still concluded that the non-pharmacological therapy used was able to greatly reduce costs.

In another paper, Blanchard, Andrasik, Appelbaum, et al. (1985) compared what they termed the “cost-effectiveness” of two types of non-pharmacological therapy; however, no comprehensive cost assessment was employed. The duration of patient-therapist contact was used as a proxy for cost, and cost-effectiveness was calculated as the percentage improvement in the headaches divided by the total time the patient was in contact with a therapist. Patients with tension-type, migraine, or combined migraine and tension-type headaches kept a diary on the characteristics of their headaches for a 4-week baseline period prior to treatment. Patients were matched into dyads based on their headache characteristics and demographic characteristics and then randomly assigned to clinic-based or home-based relaxation and biofeedback training. One month after training, they were reassessed for changes in the number, frequency, duration, and severity of their headaches, as well as the number and types of medications used to treat them. The authors concluded that home-based relaxation and biofeedback training was significantly more cost-effective than the office-based approach which involved more contact with the therapist. No long term follow-up was done to see if treatment had lasting effects.

In a slightly later study from the same group of investigators, Attanasio, Andrasik, and Blanchard (1987) randomized 25 tension-type headache patients to one of three treatment groups after a four-week baseline assessment of their headache activity. The authors saw no significant difference in the effect of treatment on cost-effectiveness for patients receiving office-based cognitive and relaxation therapy, home-based cognitive therapy alone, or home-based relaxation therapy alone. The small sample size of this study may have prevented the authors from identifying what may be small differences in the effectiveness of these treatment modalities.

### Work Loss

Consultation with a health care provider, the use of emergency and in-patient hospital services, and the use of pharmacological and non-pharmacological treatments all result in direct medical costs. Work loss due to headache, on the other hand, is an indirect cost. It is difficult to place a dollar value on activities not performed because a person was unproductive or bedridden due to headache. Ordinarily, researchers classify a study subject's job title and assign an average wage for that job, then divide the subject's salary by the number of days absent from work to reach a dollar figure representing work loss. Most of the studies reviewed in this report stopped short of this step and simply quantified rates of absenteeism and (in some cases) reduced effectiveness (see Evidence Table 6 for descriptions of all the included studies). Without further information it is very difficult to understand the full impact of chronic headache on job performance and productivity.

Table 7 summarizes data from the included studies on mean days of work lost per year due to headache. Jones and Harrop (1980) surveyed employees of General Foods, Ltd. in the United Kingdom returning to work after an absence due to headache. In the 8-month study period, 98 employees reported 281 absences from work due to headache, with an average rate of absence of 4.3 days per year.

Table 7 Mean days of work lost per year due to headache

Study | Country | Headache type | Population | Days of work lost (annualized)
Clarke, MacMillan, Sandhi, et al., 1996 | U.K. | migraine | employee | 2.0
Green, 1977 | U.K. | migraine | community | 4.0
Jones and Harrop, 1980 | U.K. | migraine | employee | 4.3
Osterhaus, Gutterman, and Plachetka, 1992 | U.S. | migraine | specialty clinic | 14.3
Stang and Osterhaus, 1993 | U.S. | migraine | community | 4.0^*^
van Roijen, Essink-Bot, Koopmanschap, et al., 1995 | Netherlands | migraine or migraine + tension-type | community | 3.9 (women) 1.0 (men)
Newland, Illis, Robinson, et al., 1978 | U.K. | migraine or non-migraine headache | community | 3.7 (men only)
Micieli, Frediani, Cavallini, et al., 1995 | Italy | episodic headache (migraine, cluster, or tension-type) chronic tension-type migraine + tension-type | specialty clinic | 61.2 44.4 28.8

* Restricted activity days, including bedridden days.

In another survey of a working population, Clarke, MacMillan, Sondhi, et al. (1996) examined employees of the Royal Hull Hospital in the United Kingdom. They found an average of two absences from work per year due to migraine. This rate of absence, if extrapolated to all migraine sufferers working in the National Health Service (NHS) in the U.K., would equate to approximately 20% of all the sick days taken per year by NHS employees. In addition, the Royal Hull Hospital employees reported an average of 15.5 days per year spent at work with a headache, 12.4 of these days with migraine. At a reported effectiveness of 56% while working with migraine, this equates to another 5.5 days of absence per year.

In a community-based survey of the Dutch population by van Roijen, Essink-Bot, Koopmanschap, et al. (1995), 10% of female and 2% of male migraineurs reported absence from work due to headache in a 2-week period. On the basis of these 2-week figures, female migraineurs averaged 3.9 days/year absent from work due to headache; males averaged 1.0 days/year. However, these figures only apply to the small percentage of migraineurs who reported any work loss. In this same population of migraineurs, 25% reported that they should have worked additional hours at their jobs to make up for lost productivity due to the effects of migraines suffered during working hours. Women reported that they had lost 23 hours of productivity due to migraine in 1 year; men lost 19 hours. Women estimated that they worked at 73% effectiveness during a migraine attack; men at 69% effectiveness.

A similar rate of work loss due to migraine was reported by Stang and Osterhaus (1993) based on data from the National Health Interview Study. In this study, a random sample of the U.S. population was asked a variety of questions about migraine headache. Those with migraine reported an average of 4 days per year spent in bed with a headache. This study also reported an additional 1.8 days of restricted activity for every day spent in bed. The authors calculated that there are 9,008,418 adults over age 18 with migraine in the United States, with the result that 36,033,672 work days per year are lost in the United States due to migraine.

Stewart, Lipton, and Simon (1996) reported the results of a follow-up survey to the American Migraine Study. In this second survey of respondents age 18 years or older with at least a 1-year history of migraine, they examined work loss due to migraine and effectiveness at work during migraine attacks. Respondents were asked to provide information on only their most severe headaches. The authors calculated Lost Work Day Equivalents (LWDEs) based on the number of days actually absent due to migraine and the number of days spent at work during a migraine attack. For days spent at work during an attack, the subjects' reported effectiveness while at work was taken into account. The average number of LWDEs was not reported, but investigators found that fewer than half of the migraine sufferers accounted for over 90% of LWDEs. Among women, the best predictor of higher LWDEs was the duration of migraine; among men, it was severity of the migraine attack.

In a population-based survey of adults in Southampton, England, Newland, Illis, Robinson, et al. (1978) identified subjects with headache, also recording whether patients typically had any of three symptoms of migraine: unilateral distribution, warning, and nausea. Among the 2,066 respondents, 686 men and 917 women reported some type of headache in the previous year. Work loss averaged 3.7 days in the previous year among the 655 men for whom work loss data were available. No work loss occurred in the 192 men who reported no migraine features with their headaches. No data on work loss were reported for women.

In a study of migraineurs who had been previously enrolled in clinical trials, Osterhaus, Gutterman, and Plachetka (1992) reported a higher average rate of work loss. In this study, 501 of 648 respondents were employed. About half of the employed respondents reported any absence from work due to headache: 29 of 56 (52%) men and 250 of 445 (56%) women. The average number of missed work days per year for these men and women were 30 and 25.2 days, respectively. However, If the number of absences were averaged over the entire population of employed respondents, the rate would drop to 15.5 days per year for men and 14.2 days per year for women.

Micieli, Frediani, Cavallini, et al. (1995) looked at work loss in a group of patients recruited from two specialty headache clinics in Italy. This study found a higher rate of absence among these clinic patients than either Osterhaus, Gutterman and Plachetka (1992), in a similar clinic population, or others in studies of the general population. Furthermore, 58.5% of migraine patients and 70.6% of tension-type headache patients in this study reported that headaches suffered during work were completely debilitating.

Other researchers report work loss in a slightly different way. Rasmussen, Jensen, and Olesen (1992) surveyed people living in western Copenhagen County (Denmark). They found that 43% of employed migraineurs reported at least one absence from work per year due to migraine. Of this same subset, 91 % were absent less than 7 days/year while 9% were absent between 7–14 days/year. Of those with tension-type headache, 12% were absent at least once because of headache and 16% were out for more than 14 days.

Breslau and Davis (1993) also reported data on migraine and work loss. This study examined the relationship between migraine, physical health, and mental health in a sample of 1,200 persons, ages 21–30, enrolled in a southwest Michigan health maintenance organization. One of the outcomes reported by the authors was that subjects who suffered from migraine had greater limitations in activity due to their health and greater absence from work in the month previous to the study than did controls (30.9% of migraineurs versus 18.7% of controls).

Edmeads, Findlay, Tugwell, et al. (1993) reported on a population-based survey of Canadian headache sufferers. Subjects reported that 11% of their migraines caused them to leave or be absent from work. However, this study did not report the average number of days of absence from work. Celentano, Stewart, Lipton, et al. (1992) studied the amount of disability caused by headache. Among women, 11.2% reported no disability due to migraine, 50.8% mild disability, and 36.9% moderate/severe disability. In men 15.3% reported no disability, 53.0% mild disability, and 30.7% moderate/severe disability. In this case, moderate to severe disability was characterized as requiring bed rest, absence from work, and an inability to perform routine daily activities.

Linet, Stewart, Celentano, et al. (1989) asked subjects 12 to 29 years old identified by a telephone survey in Washington County, MD, how often they missed work or school because of headache. Cases were based upon Ad Hoc criteria for migraine determined in a telephone interview. For days when they had headaches, 85.9% of women and 91.7% of men reported that they would not be absent from work or school, 10.2% of women and 6.1 % of men said that they would be absent half of the day, and 3.7% of women and 1.8% of men said they would be absent all day.

These data are quite different from those reported by Stewart, Lipton, and Liberman (1996), who sampled residents of Baltimore County, MD, ages 18 to 65, using random digit dialing. Among subjects meeting IHS criteria for migraine, 33% of women and 44% of men said they would not be absent from work due to headache, 31% of women and 31% of men would rarely be absent, 16% of women and 11% of men would be absent less than half of the day, and 20% of women and 15% of men say they would be absent more than half of the day. It is evident that the populations identified in these two studies were different; the differences may be due to differences in age or in diagnostic criteria.

Although Kryst and Scherl (1994) did not report days of absence or disability due to headache, 37.9% of respondents with migraine in the Kentucky Health Survey said that headaches affected their attendance at work or school.

Mounstephen and Harrison (1995) surveyed employees of a chemical manufacturing and research firm in the United Kingdom regarding the duration and frequency of their migraine headaches. Most subjects reported a slight to moderate effect of migraine on their work. Headache-related absence was reported by 24.2% of migraineurs. Based on the responses of 62 migraineurs these authors calculated that women would experience an average of 144 hours of migraine symptoms per year. For men this number was estimated to be 44 hours per year. It could be expected that a significant number of these migraine headache affected hours would occur at work. However, the authors did not collect specific information on work loss due to migraine.

One study examined the effect of race on absence from work and disability. Stewart, Lipton, and Liberman (1996) found no differences in the frequency of missed work days by race. However, they did report that black women and men were less likely to report reduced efficiency at work than either whites or Asian-Americans. They also reported that men and women experience similar reductions in effectiveness with their headaches. No reduction in effectiveness was reported by 9% of women and 11 % of men, a less than 25% reduction was reported by 22% of women and 23% of men, a 25–49% reduction in 35% of women and 37% of men, a 50–74% reduction by 17% of women and 13% of men, and a 75% or greater reduction by 17% of women and 17% of men. Clarke, MacMillan, Sondhi, et al. (1996) reported that subjects estimated that they worked only 56% as effectively when they were suffering from migraine headache.

While headache does cause a large number of absences from work, it appears that many headache sufferers stay on the job, functioning with significantly reduced effectiveness, when they have a headache. Days of work lost vary remarkably among different countries; cultural differences, rather than biological differences, may explain some between-country differences in work loss. There have been few efforts to estimate the economic effect of this lost productivity. The price of errors or inaccuracies in work performed during a headache attack may never be known.

## Conclusions

Despite the fact that large numbers of Americans suffer from chronic headache, little research has been done to assess how this condition affects the utilization of health care resources, quality of life, and personal productivity. The published studies provide only a glimpse of some resource utilization and economic issues related to chronic headache, usually migraine. Characterizing patients with chronic headache is problematic, even with the aid of the IHS diagnostic classification, and study populations may still exhibit remarkable diversity. Interpreting the generalizability of the results reported in clinical studies is difficult.

Perhaps the most striking finding highlighted by the studies reviewed in this report is the low rate of health care provider diagnosis of chronic headache conditions. While between 56% and 91 % of chronic headache sufferers seek the care of a health care provider, only one-third report having received a diagnosis of their condition. The literature reviewed did not address the number of provider visits required or the number and type of tests utilized to make the diagnosis. Those who never receive a definitive diagnosis for their headache symptoms will most likely continue to seek answers from a health care provider and try to find relief from non-prescription medications. Access to and knowledge of the health care system probably play an important role in receiving a diagnosis. While it is likely true that those people with the most severe and frequent headaches have a better chance of receiving a diagnosis, it is also likely that there are many more people with moderately disabling headaches who could benefit from medical treatment.

Whether or not an individual with chronic headache receives a specific diagnosis of migraine, tension-type headache, or some other syndrome, such an individual tends to be a frequent user of health care resources such as provider office visits, emergency department visits, inpatient admission, and pharmaceutical therapies. Another issue not addressed by the literature is identification of patterns with which these resources are used. For example, we do not know if people who regularly see their health care provider also use the emergency department for care or if the emergency department is more likely to be used by those who have no other regular source of care. Also, we do not know why people with chronic headache are hospitalized, or if there are common treatment protocols used for patients hospitalized for headache.

Some patients with chronic headache have a high number of contacts with the medical establishment. Osterhaus, Gutterman, and Plachetka (1992) reported that 7.6% of the subjects in their study made 12 or more visits to a physician per year for the care of their headaches. The reasons why some patients have such a high number of visits has not been studied. Some patients may be receiving in-office treatment for acute headache attacks; others may be seeking reassurance that their headache symptoms are not caused by some other life-threatening illness; still others may be experiencing unwanted side-effects of medications and searching for satisfactory pain relief.

On the other hand, many individuals with chronic headache pain never seek the care of a doctor, or after some period of time become discouraged with the ability of organized medicine to provide relief. This causes them to discontinue their care and, most likely, their access to prescription medications. The reasons why people with chronic headache discontinue care have not been thoroughly examined. Edmeads, Findlay, Tugwell, et al. (1993) began to elucidate some aspects of this question. Some patients feel that their headaches are not severe or frequent enough to warrant medical attention; others were unhappy with the care their physician provided, experienced negative side-effects of prescription medications, or had found over-the-counter medications which were able to treat their headaches.

This not infrequent rejection of regular medical care should not be interpreted as a savings in health care costs. Although satisfactory studies have not been done, it is possible that individuals who do not receive regular medical care for their headaches may suffer negative consequences of self-medication such as rebound headaches, or may be less productive in the home or work place because they lack regular medical monitoring of their condition.

Most individuals with chronic headache rarely or never use the emergency department for the treatment of their headaches. Similarly, few are ever hospitalized. However, a small but notable percentage of patients—probably between 5% and 20%—do use these resources. We do not know the precise reasons for these encounters or whether they are medically necessary.

Probably related to the large percentage of undiagnosed headache sufferers is the large number of people who rely on non-prescription medications to treat their symptoms. While this may not be related to a lack of ongoing medical care in all cases, it is likely that there is some relationship. Some chronic headache sufferers may believe that their symptoms are not frequent or severe enough to warrant the use of prescription medication, and others may have experienced unwanted side-effects. Nevertheless, there are probably many who would benefit from prescription medication. Also, there is the finding of Edmeads, Findlay, Tugwell, et al. (1993) that 10% of their survey population were using prescription medications to treat their headaches without the supervision of a physician.

Another point underscored by the studies reviewed for this report was the low number of patients using preventive drug treatment for their headaches. It might be the case that patients had not been offered preventive medications, had not tolerated them, or that their providers were not aware of the availability of these medications. A major area that has not been addressed in the literature is the description of the treatment received by chronic headache patients when they see a health care provider. It appears that some patients become discouraged by the lack of a diagnosis, medications which do not adequately relieve their symptoms, or by the side-effects of medications. The type of patient education these individuals receive and the prognoses they are given are unknown.

Also unclear is what emphasis, if any, is placed on non-pharmacological therapies such as biofeedback, cognitive therapy, and stress management or alternative therapies including acupuncture, hypnosis, spinal manipulation, and massage. Although there is very little published literature on the costs of non-pharmacological therapy, this alternative to drug-based management of chronic headache may be a useful and cost-effective tool in the treatment of this patient population.

Finally, several studies have documented the magnitude of work loss and reduced productivity due to headache. While the mean number of days absent from work annually appears to vary roughly from about 2 to 14 for chronic headache sufferers, there has been little systematic effort to translate these missed days into corresponding estimates of economic loss from either the societal or individual perspective. Also requiring much more study is the impact on productivity of headaches that impair worker performance, but do not lead to work loss days.

## Future Research

Reliable, comprehensive, and generalizable information on the cost of headache has multiple important uses: for gauging the overall economic burden of headache in comparison with other problems; for use in cost-effectiveness analyses of preventive and therapeutic interventions; and for informing the development of clinical practice guidelines. For this report we surveyed the published literature on the cost of headache and summarized the key findings from papers reporting primary data that appeared to be both relevant and of adequate quality. We find that each paper reviewed here provides some useful information about the economic cost of headache. But no study attempts to estimate the total cost for a nationally representative population of sufferers.

Coming closest to offering a comprehensive assessment of the resource use implications of headache are the analyses by Osterhaus, Gutterman, and Plachetka (1992); Stang and Osterhaus (1993); and Clouse and Osterhaus (1994). But these studies focus on migraine only, so that the costs of tension-type, cluster, and other chronic primary headache disorders remain to be estimated. And there are other, more specific limitations to the three studies. The first studied a population (migraineurs in specialty clinics who had participated in clinical trials) that is arguably not nationally representative of headache sufferers. The second was not able to sort out emergency room use. The third could not examine work loss. None of these studies could present data on non-prescription drug use and none could report on non-pharmacological therapy. None of this is intended as a criticism of these studies, which were well-executed and limited primarily by the nature of the available data. Rather, it is to set the stage for arguing that to produce reliable, comprehensive, and generalizable estimates of the economic cost of headache, good quality resource utilization information from multiple, complementary data sources almost certainly will be required.

In this concluding section, we present an analytical framework for identifying the required data elements and carrying out the calculations. This framework is built around standard economic models of disease cost. For each parameter or variable in the cost models, the questions of interest then become: What type of data is required? Where can it be found? How difficult, or expensive, will it be to acquire? Thus, we first present the framework and then briefly discuss potential data sources.

### Analytical Framework

At least two important definitional issues must be addressed at the outset. Since costs will vary both by type of headache and the demographic and clinical makeup of the study population, estimates of total costs should be derived as the sum of costs across headache and patient types. This, in tum, requires operational definitions for headache types and patient types. For concreteness, we illustrate below.

#### Headache Types

Let the general term “headache” be further classified now into three categories: migraine headache (subdivided into “migraine” and “migraine variants”), tension-type headache, and other unspecified headaches.

In terms of the International Classification of Diseases, 9th Revision, Clinical Modification (ICD-9-CM) codes (U.S. Department of Health and Human Services, 1994), these three categories can be defined as follows:

[underlined: Migraine:]
346.0 | Classical Migraine; - - with focal neurological phenomena; - - with aura
346.1 | Common Migraine; - - atypical; - - sick headache
346.8 | Other Migraine; - - hemiplegic; - - opthalmoplegic
346.9 | Other migraine, unspecified
[underlined: Migraine Variants:]
346.2 | Variants of Migraine; - - cluster; - - histamine; - - Horton’s neuralgia; - - neuralgia (ciliary, migrainous)
[underlined: Tension Headache:]
307.81 | Tension Headache (psychalgia)
[underlined: Other, Unspecified Headache:]
784.0 | Headache; - - facial pain; - - pain in head NOS; - - excludes atypical face pain, migraine, tension headache

#### Patient Types

It is generally accepted that headache costs will vary by age and sex, and they may also vary by race and geographic region. Fundamentally, this is because the direct medical costs associated with headache will depend heavily on the individual’s frequency of headaches (by type); underlying health status (including comorbidities); overall economic status, which directly influences financial access to care; and proclivity to use medical care (controlling for financial access). Similarly, the indirect (work loss) costs of headache will be a function of the individual’s labor force participation and relative wages. Since the patient’s health status, overall economic status, proclivity to use medical care, and labor market earnings are all strongly correlated with age, sex, and race, these demographic variables may usefully serve to define our patient types. It is reasonable to suggest, but requires further scrutiny to conclude, that headache costs will vary geographically (all else equal) because of variations in provider practice styles.

#### Cost Models

Establishing the unit of analysis: Cost per episode vs. cost per period. Headache exhibits characteristics of both a chronic and an acute disease. In the course of a given year, an individual may suffer recurrent attacks of sharp, but time-limited pain. In direct response to some of these acute events, the individual may seek medical care or miss time from work or be less productive on the job. For other acute headache events, the individual may not seek medical care as such, but find other means of coping (including just “watchful waiting”). Moreover, in anticipation of such acute events, the individual may purchase medications or spend time and money seeking preventive care, e.g., behavioral therapy.

Thus, it is no simple matter to derive an operational definition of the headache “episode,” nor to capture all of the direct and indirect costs associated with any such episode. In the discussion that follows, an episode refers basically to the acute, time-limited pain event referred to above, but with recognition that its precise moments of onset and termination will likely not be discernible in any economic or clinical data base accessible to investigators. However, one may be able to make rough inferences about the occurrence rates for headache episodes for specific types of patients from two types of available information: (1) claims data reporting the direct medical costs for headache, and (2) survey data yielding reported rates of acute events.

Because new headache guidelines, or cost-effectiveness analyses generally, may alter the cost associated with headache by altering the frequency and/or intensity of episodes, we first present a cost model below (the detailed model) that specifically includes episode rates, by patient type. But because the available data may or may not prove adequate to support an episode-level model, we next present an alternative formulation (the aggregated model). For either model, the summary outcome of interest is total headache-related cost per year, computed as the sum of total direct and total indirect cost per year.

Both models focus on headache-specific costs, while holding all other health-related costs in the background. The alternative “all-cost” approach—in which the total health-related costs for headache sufferers are compared with the total health-related costs for a “comparison sample” of otherwise similar individuals—is not pursued here. Defining and then finding appropriate comparison samples are both formidable tasks in the present context. Rather, we assume that headache-related costs can be parsed out or extracted directly, and to a satisfactory degree, from the combination of data sets (based variously on insurance claims records, patient surveys, and relevant published literature) to be discussed subsequently.

Detailed model. In the notation that follows, the parameter j refers to headache type, i refers to patient type, and h indexes the number of (acute) episodes per year. Headache cost may then be computed as follows:

C ( Direct )_i j_ = Σ_h_ p ( X_i j h_ ) X_i j h_ • { p_i j_ ( y | x ) [ C_i j_ ( Y ) + C_i j_ ( Z_1_ ) ] + [ 1 - p_i j_ ( y | x ) ] C_i j_ ( Z_2_ ) } C ( Indirect )_i j_ = Σ_h_ p ( X_i j h_ ) X_i j h_ • { p_i j_ ( w l | x ) W L_i j_ ( W g_i_ ) + p_i j_ ( p e | x ) [ ( 1 - P E_i j_ ) D D_i j_ ( W g_i_ ) ] } C ( Total )_i j_ = C ( Direct )_i j_ + C ( Indirect )_i j_ .

If there are N_ij_ individuals of patient type i meeting the criteria for headache type j, then total cost per year is

C ( Total ) = Σ_i_ Σ_j_ N_i j_ C ( Total )_i j_ ,

where

- (1) X_ijh_ denotes h headaches of type j for a patient of type i per year
- (2) p(X_ijh_) is the probability of exactly X_ijh_
- (3) p_ij_(y|x) is the probability of a claims-generating encounter, given a headache episode of type j for a patient of type i
- (4) C_ij_(Y) is the average claims-based cost per episode, given j and i
- (5) C_ij_(Z_1_) is the average cost of resources consumed as part of claims-based encounter but not included in claims
- (6) C_ij_(Z_2_) is the average cost of non-claims-based treatment per episode
- (7) p_ij_(wl|x) is the probability of any work loss days, given a headache episode
- (8) WL_ij_ is the average work loss days per episode, given any work loss days
- (9) Wg_i_ is the average daily wage rate for patient type i
- (10) p_ij_(pe|x) is the probability of partial effectiveness at work, given an episode
- (11) PE_ij_ is the average partial effectiveness at work, given an episode
- (12) DD_ij_ is the average number of days of partial effectiveness at work per episode.

Note that depending on the form of the data, one might make use of the following simplifying relationship:

Σ_h_ p ( X_i j h_ ) X_i j h_ = X ( Mean )_i j_ ,

where

- (13) X(Mean)_ij_ is the average number of headache episodes per year, given i and j.

Aggregated model. Suppose now that we cannot adequately ascertain headache frequency at the individual level, or that direct costs are deemed to be so non-linearly related to the occurrence of episodes that the functional form of the model above appears unrealistic. Then one could adopt the following type of specification:

C ( Direct )_i j_ = C_T i j_ ( Y ) + C_T i j_ ( Z_1_ ) + C_T i j_ ( Z_2_ ) C ( Indirect )_i j_ = W L_T i j_ ( W g_i_ ) + [ 1 - P E ( Mean )_i j_ ] D D_T i j_ ( W g_i_ ) ,

where

- (14) C_Tij_ is the total annual claims-based cost for headache type j for a patient of type i
- (15) C_Tij_ (Z_1_) is the total annual cost for resources consumed in claims-based encounters but not included in claims, given i and j
- (16) C_Tij_(Z_2_) is the total annual cost for non-claims-based treatment of headache, given i and j
- (17) WL_Tij_ is the total work loss days due to headache per year, given i and j
- (18) DD_Tij_ is the total disability (but not work loss) days per year due to headache, given i and j
- (19) PE(Mean)_ij_ is the average value of partial effectiveness for disability-affected days on the job, given i and j.

With either the detailed or the aggregated model, a diverse array of data would be needed for estimating the parameters defined above. We conclude with a brief review of potential data sources and a preliminary assessment of the extent to which they would be adequate in concert to support new, comprehensive estimates of the cost of headache.

### Potential Data Sources

#### Insurance Claims Records

With claims data, one can track the health care utilization and cost over time of a well-defined sample of individuals. For each recorded encounter, data are generally available on the reason for visit or admission, the individual’s clinical status as captured by ICD-9-CM codes, medical procedures performed as captured in Current Procedural Terminology (CPT™) codes (American Medical Association, 1998), and demographic descriptors.

A strength of such data is that, in theory, they reflect a reliably recorded history of events from which medical care resource consumption can be directly inferred. Two acknowledged limitations, however, are that data will be available for covered services only, and detailed clinical data on the patient, as found in the medical record, will not generally be available. Thus, for the headache sufferer, if non-pharmacological treatments are not among the services covered by the insurance plan (as is typically the case), claims data can reveal nothing about their utilization. In addition, work loss and other measures of non-medically related cost due to headache (e.g., caregiver hours devoted to the migraine sufferer) will not be found in claims data. Finally, measures of the economic opportunity cost of services are generally not reported directly in claims data, but must be inferred through the application of cost-to-charge ratio techniques and other approaches; see Lave, Anderson, Brailer, et al. (1994) for an overview of how claims data have been used recently for estimating the cost of health services.

Currently, claims data may be obtained from several sources:

Data pooled across employer-based health plans. A prime example is the commercially available MEDSTAT MarketScan® database (MarketScan® Databases [computerized database], 1998), which compiles the claims of approximately 7 million individuals enrolled in benefit programs sponsored by large employers located throughout the U.S. Not all benefit plans offer the same degree of covered services; so outpatient prescriptions may be covered under one plan but not another. In general, these data reflect the utilization of acute care services by privately insured middle-income families of working age. Since chronic headache does not discriminate by income group and is probably most prevalent among persons age 25–55, databases like MarketScan® would appear to be potentially important sources of cost information.

Medicare and Medicaid. The Medicare data set is compiled and maintained by the Health Care Financing Administration (HCFA). Medicare data include claims for inpatient and outpatient services provided to patients age 65 and over and to disabled persons under age 65. These data are of generally good quality, but lack information on outpatient prescription drugs and long-term care services. As noted above, chronic headache (while found among those over age 65) is most prevalent in the non-elderly.

The Medicaid data set is also compiled and maintained by HCFA, but is limited in some important respects. By construction: only Medicaid eligibles are followed, thus generally limiting the focus to lower income persons. Since eligibility varies across states and any individual’s own eligibility within a given state may also vary year by year, obtaining reliable and comparable longitudinal data is problematic. Moreover, there is still considerable variation across states in the quantity and quality of the claims data reported to HCFA.

Thus, while each of these well-known data sources may be of some use in estimating the direct medical cost of headache, there are substantial limitations. It may be the case, however, that a careful analysis of appropriate subsets of Medicaid claims can yield sound observations of resource use for lower income persons; this would serve to complement the analyses from datasets like MarketScan®, where the focus is necessarily on families above the poverty line.

Medical care organizations (MCOs). Yet to be exploited in a large-scale way are claims and clinical data collected routinely by health maintenance organizations and other MCOs which act as both provider and insurer for well-defined patient populations. Ideally, such data would come from relatively large MCOs, providing comprehensive services to many thousands of persons at a diverse set of geographic sites.

#### Survey Data

An important advantage of collecting utilization and cost information through patient surveys is that, in principle, a comprehensive accounting of the resource impact of disease can be obtained. Questions can be tailored to suit the particular disease under examination, and statistically representative samples of persons can be interviewed. An important limitation, however, is that self-reported information is almost always at some risk to recall bias; ideally, such data would be validated by selectively comparing survey responses with clinical and administrative data.

For studying headache costs in the U.S., at least three surveys appear to hold considerable promise: (1) the American Migraine Study (Celentano, Stewart, Lipton, et al., 1992), (2) the Baltimore County Prevalence Study (Stewart, Lipton, and Liberman, 1996), and (3) the Baltimore County Diary (and Telephone) Study (also Stewart, Lipton, and Liberman, 1996).

- The American Migraine Study was conducted in 1989 on a national probability sample of migraine patients aged 12–80 years; see Lipton and Stewart (1993); Celentano, Stewart, Lipton, et al. (1992); and Linet, Stewart, Celentano, et al. (1989). Migraine diagnosis was validated using International Headache Society criteria. This survey contains more than 60 questions covering severity and type of symptoms, resource utilization, willingness to pay for care, insurance, and occupation. One limitation is that only persons with relatively severe migraine were included.
- The Baltimore County Project was conducted in 1993–1994 and limited to persons residing in that part of Maryland (Stewart, Lipton, and Liberman, 1996). The project was conducted in several phases, beginning with a telephone survey of 13,000 persons to determine the prevalence of headache (not necessarily migraine). The screening instrument used did not include questions related to headache costs. In the second phase, respondents reporting signs and symptoms of migraine were asked to undergo confirmatory medical examinations. In a third phase, a sample of 260 persons with a clinically confirmed diagnosis of migraine participated in a 3-month diary study. The daily entries focused on the presence or absence of a headache during the 24-hour period, symptoms and severity of the headache, types of medications taken, whether hours at work were lost, and percentage effectiveness at work. The first phase of this project yielded data with better diagnostic accuracy than the American Migraine Study, with 97% sensitivity and 86% specificity.

A limitation of both the American Migraine and the Baltimore County studies is their exclusive focus on migraine headache. But they well illustrate the potential for survey data to fill in the gaps left by claims data and our third source of cost information, the published literature.

#### Published Literature

Although most of the studies we identified in the published literature individually yield useful information, in sum they do not provide adequate data for the analyst to construct a reliable, comprehensive, and generalizable picture of the cost of headache. Nonetheless, the published literature should still be regarded as a potentially important source of data for headache cost analyses. Excellent studies will no doubt continue to be published, providing results that may usefully be incorporated into future primary cost analyses.

#### Mapping Cost Model Variables to Potential Data Sources

To see how claims and survey data might be used in implementing the detailed and aggregated headache cost models presented above, see Table 8. For each variable or parameter, we indicate whether relevant data appear to be available from MEDSTAT, the American Migraine Study, or the various phases of the Baltimore County Project.

Table 8 Availability of information for headache cost models

Variable or Parameter | MEDSTAT MarketScan® | American Migraine | Baltimore County Study
Variable or Parameter | MEDSTAT MarketScan® | American Migraine | Telephone Survey | Medical Examination | Diary
1) # of headaches, type of headache, type of patient | | X | X | | X
2) probability of 1) | | X | X
3) probability of a claims producing encounter for patient and headache type | | X | | X
4) average claims-based cost/encounter | X
5) average cost of resources consumed as part of claims-based encounter but not included in claims | X | X | | X | X
6) average cost of non-claims-based treatment per headache | | X | X | X | X
7) probability of work loss day | | X | X
8) work loss days per headache | | X
9) daily wage average | | X
10) probability of patient effectiveness during headache | | X | X | | X
11) average patient effectiveness/day | | X | X | | X
12) average number of days of partial effectiveness | | X
13) average number of headaches/year | | X
14) total annual claims-based cost for headache type and patient type | X | X | | X
15) total annual cost for resources consumed in claims-based encounters but not counted in claims | X | X | | X
16) total annual cost for non-claims-based treatment for headache | | X | | X
17) total work loss days due to headache | | X
18) total disability but not work loss days per year due to headache | | X
19) average value of partial effectiveness on disability days | | X
Patient type (i) | X | X | X
Headache type (j) | X | X | X

We tentatively conclude that if these data sources were used in concert, all components of our cost models could be estimated—at least for migraine headache. Producing comparable cost estimates for tension-type and other headache types remains a major challenge. But the way forward in all cases will almost certainly call for creative efforts to combine data from a variety of sources.