# References

Adelman JU, Vonseggern R. Cost considerations in headache treatment. 1. Prophylactic migraine treatment. Headache. 1995;35(8):479-87. [pmid: 7591743].
Akpek S, Arac M, Atilla S, Onal B, Yucel C, Isik S. Cost-effectiveness of computed tomography in the evaluation of patients with headache. Headache. 1995;35(4):228-30. [pmid: 7775181].
American Medical Association. CPT™ ‘98: Physicians’ Current Procedural Terminology. Chicago, IL. American Medical Association. 1998.
Appleby J. Data briefing. Migraine. Health Serv J. 1996;106(5498):34-5.
Attanasio V, Andrasik F, Blanchard EB. Cognitive therapy and relaxation training in muscle contraction headache: efficacy and cost-effectiveness. Headache. 1987;27(5):254-60. [pmid: 3110104].
Baker HL Jr. Cranial CT in the investigation of headache: cost-effectiveness for brain tumors. J Neuroradiol. 1983;10(2):112-6. [pmid: 6410008].
Beaty ET, Haynes SN. Behavioral intervention with muscle-contraction headache: a review. Psychosom Med. 1979;41(2):165-80. [pmid: 108756].
Becker L, Green L, Beaufait D, Kirk J, Froom J, Freeman W. Detection of intracranial tumors, subarachnoid hemorrhages, and subdural hematomas in primary care patients: a report from ASPN, Part 2. J Fam Pract. 1993a;37(2):135-41. [pmid: 8336093].
Becker L, Green L, Beaufait D, Kirk J, Froom J, Freeman W. Use of CT scans for the investigation of headache: a report from ASPN, Part 1. J Fam Pract. 1993b;37(2):129-34. [pmid: 8336092].
Becker L, Iverson D, Reed F, Calonge N, Miller RS, Freeman W. Patients with new headache in primary care: a report from ASPN. J Fam Pract. 1988;27(1):41-7. [pmid: 3392508].
Becker WJ, Riess CM, Hoag J. Effectiveness of subcutaneous dihydroergotamine by home injection for migraine. Headache. 1996;36(3):144-8. [pmid: 8984085].
Blanchard EB, Andrasik F, Appelbaum KA, Evans DD, Jurish SE, Teders SJ, Rodichok LD, Barron KD. The efficacy and cost-effectiveness of minimal-therapist-contact, non-drug treatments of chronic migraine and tension headache. Headache. 1985;25(4):214-20. [pmid: 3926719].
Blanchard EB, Jaccard J, Andrasik F, Guarnieri P, Jurish SE. Reduction in headache patients’ medical expenses associated with biofeedback and relaxation treatments. Biofeedback Self Regul. 1985;10(1):63-8. [pmid: 3910117].
Breslau N, Davis GC. Migraine, physical health and psychiatric disorder: a prospective epidemiologic study in young adults. J Psychiatr Res. 1993;27(2):211-21. [pmid: 8366470].
Broadhead WE, Larson DB, Yarnall KS, Blazer DG, Tse CK. Tricyclic antidepressant prescribing for nonpsychiatric disorders. An analysis based on data from the 1985 National Ambulatory Medical Care Survey. J Fam Pract. 1991;33(1):24-32. [pmid: 2056287].
Burke EJ, Andrasik F. Home-vs. clinic-based biofeedback treatment for pediatric migraine: results of treatment through one-year follow-up. Headache. 1989;29(7):434-40. [pmid: 2503466].
Business & Health. Special report. Controlling headache costs. Bus Health. 1992:6-30.
Cady RK, Shealy CN. Recent advances in migraine management. J Fam Pract. 1993;36(1):85-91. [pmid: 8380430].
Carrera GF, Gerson DE, Schnur J, McNeil BJ. Computed tomography of the brain in patients with headache or temporal lobe epilepsy: findings and cost-effectiveness. J Comput Assist Tomogr. 1977;1(2):200-3. [pmid: 97333].
Celentano DD, Linet MS, Stewart WF. Gender differences in the experience of headache. Soc Sci Med. 1990;30(12):1289-95. [pmid: 2367875].
Celentano DD, Stewart WF, Lipton RB, Reed ML. Medication use and disability among migraineurs: a national probability sample survey. Headache. 1992;32(5):223-8. [pmid: 1628958].
Clarke CE, MacMillan L, Sondhi S, Wells NE. Economic and social impact of migraine. Q J Med. 1996;89(1):77-84.
Clouse JC, Osterhaus JT. Healthcare resource use and costs associated with migraine in a managed healthcare setting. Ann Pharmacother. 1994;28(5):659-64. [pmid: 8069007].
Cohen JA, Beall DG, Miller DW, Beck A, Pait G, Clements BD. Subcutaneous sumatriptan for the treatment of migraine: humanistic, economic, and clinical consequences. Fam Med. 1996;28(3):171-7. [pmid: 8900548].
Cull RE, Wells NEJ, Miocevich ML. The economic cost of migraine. Brit J Econ. 1992;2:103-15.
Cypress BK. Headache as the reason for office visits, National Ambulatory Medical Care Survey: United States, 1977–78. Adv Data. Jan. 7. 1981;(67):1-6.
Dahlöf CG. Health-related quality of life under six months’ treatment of migraine—an open clinic-based longitudinal study. Cephalalgia. 1995;15(5):414-22. [pmid: 8536303].
Davey PJ, Leeder SR. The cost of migraine: more than just a headache?. Pharmacoeconomics. 1992;2(1):5-7. [pmid: 10146975].
de Lissovoy G, Lazarus SS. The economic cost of migraine. Present state of knowledge. Neurology. 1994;44(6 Suppl 4):S56-62. [pmid: 8008226].
Demaerel P, Boelaert I, Wilms G, Baert AL. The role of cranial computed tomography in the diagnostic work-up of headache. Headache. 1996;36(6):347-8. [pmid: 8707550].
Diamond S, Medina JL. Headaches. Clin Symp. 1989;41(1):2-31. [pmid: 2686902].
Drummond MF, Richardson WS, O’Brien BJ, Levine M, Heyland D. Users’ guides to the medical literature. XIII. How to use an article on economic analysis of clinical practice. A. Are the results of the study valid?. JAMA. 1997;277(19):1522-7.
Dumas MD, Pexman JH, Kreeft JH. Computed tomography evaluation of patients with chronic headache. Can Med Assoc J. 1994;151(10):1447-52. [pmid: 7954139].
Edmeads J, Findlay H, Tugwell P, Pryse-Phillips W, Nelson RF, Murray TJ. Impact of migraine and tension-type headache on life-style, consulting behaviour, and medication use: a Canadian population survey. Can J Neurol Sci. 1993;20(2):131-7. [pmid: 8334575].
Feczko JM. Cost of sumatriptan. Lancet. 1992;340(8813):243. [pmid: 1353163].
Friedman H, Taub HA. Brief psychological training procedures in migraine treatment. Am J Clin Hypn. 1984;26(3):187-200. [pmid: 6435442].
Frolund F, Frolund C. Pain in general practice. Pain as a cause of patient-doctor contact. Scand J Prim Health Care. 1986;4(2):97-100. [pmid: 3726334].
Furlong S, Pryse-Phillips W, Crowley M, Turner CJ. Prescribing practices for the management of headache in Newfoundland and Labrador. Headache. 1996;36(9):542-6. [pmid: 8916562].
Futterman R, Hill J. Evaluation of a benefits modification for the treatment of migraine headaches among members of a managed care organization. AHSR FHSR Annu Meet Abstr Book. no date. 13:142.
Gaist D, Hallas J, Sindrup SH, Gram LF. Is overuse of sumatriptan a problem? A population-based study. Eur J ClinPharmacol. 1996;50(3):161-5.
Ganiats TG, Carson RT, Hamm R, Spann SJ, Hagen MD, Cantor SB. Population-based discounting of future health outcomes. AHSR FHSR Annu Meet Abstr Book. 1994;11:53.
Ginsberg G, Israeli A, Cohen A, Stessman J. Factors predicting emergency room utilization in a 70-year-old population. Isr J Med Sci. 1996;32(8):649-64. [pmid: 8816875].
Green JE. A survey of migraine in England, 1975–1976. Headache. 1977;17:67-68. [pmid: 863708].
Greiner DL, Addy SN. Sumatriptan use in a large group-model health maintenance organization. Am J Health Syst Pharm. 1996;53(6):633-8. [pmid: 8800968].
Hackett G. Management of migraine. Practitioner. 1994;238(1535):130-6. [pmid: 8183791].
Headache Classification Committee of the International Headache Society. Classification and diagnostic criteria for headache disorders, cranial neuralgias and facial pain. Cephalalgia. 1988;8(Suppl 7):1-96.
Hoffert MJ. Treatment of migraine: a new era. Am Fam Physician 1994. Feb. 1915;49(3):633-8.
Holroyd KA, Penzien DB. Pharmacological versus non-pharmacological prophylaxis of recurrent migraine headache: a meta-analytic review of clinical trials. Pain. 1990;42(1):1-13. [pmid: 2146583].
Hopkins A. The epidemiology of headache and migraine, and its meaning for neurological services. Schweiz Med Wochenschr. 1996;126(4):128-35. [pmid: 8578295].
Hopkins A. Lessons for neurologists from the United Kingdom Third National Morbidity Survey. J Neurol Neurosurg Psychiatry. 1989;52(4):430-3. [pmid: 2786920].
Hudzinski L, Zebrick L. Bruxism 1995. Headache Quarterly. 1996;7(1):48-53.
Ilacqua GE. Migraine headaches: coping efficacy of guided imagery training. Headache. 1994;34(2):99-102. [pmid: 8163375].
Jhingran P, Cady RK, Rubino J, Miller D, Grice RB, Gutterman DL. Improvements in health-related quality of life with sumatriptan treatment for migraine. J Fam Pract. 1996;42(1):36-42. [pmid: 8537803].
Jones A, Harrop C. Study of migraine and the treatment of acute attacks in industry. J Int Med Res. 1980;8(5):321-5. [pmid: 7418950].
Kaa KA, Carlson JA, Osterhaus IT. Emergency department resource use by patients with migraine and asthma in a health maintenance organization. Ann Pharmacother. 1995;29(3):251-6. [pmid: 7606069].
Kahn CE Jr, Sanders GD, Lyons EA, Kostelic JK, MacEwan DW, Gordon WL. Computed tomography for nontraumatic headache: current utilization and cost-effectiveness. Can Assoc Radiol J. 1993;44(3):189-93. [pmid: 8504331].
Kent J. The treatment of chronic benign pain syndrome in capitated health care. Manag Care Q. 1996;4(2):77-83. [pmid: 10157265].
Klapper JA. Toward a standard drug formulary for the treatment of headache. Headache. 1995;35(4):225-7. [pmid: 7775180].
Knaus WA, Davis DO. Utilization and cost-effectiveness of cranial computed tomography at a university hospital. J Comput Assist Tomogr. 1978;2(2):209-14. [pmid: 100533].
Knaus WA, Wagner DP, Davis DO. CT for headache: cost/benefit for subarachnoid hemorrhage. Am J Roentgenol. 1981;136(3):537-42. [pmid: 6781292].
Kozma CM, Mauch RP, Reeder CE, Lawrence BJ. A literature review comparing the economic, clinical, and humanistic attributes of dihydroergotamine and sumatriptan. Clin Ther. 1994;16(6):1037-51. [pmid: 7697683].
Kozma CM, Reeder CE. Comparison of the economic, clinical, and humanistic attributes of dihydroergotamine and sumatriptan. Clin Ther. 1995;17(2):315-9. discussion 314. [pmid: 7614531].
Kroenke K, Mangelsdorff AD. Common symptoms in ambulatory care: incidence, evaluation, therapy, and outcome. Am J Med. 1989;86(3):262-6. [pmid: 2919607].
Kryst S, Scherl E. A population-based survey of the social and personal impact of headache. Headache. 1994;34(6):344-50. [pmid: 7928313].
The Lancet. Sumatriptan, serotonin, migraine, and money. Lancet. 1992;339(8786):151-2. [pmid: 1346014].
Larson EB, Omenn GS, Lewis H. Diagnostic evaluation of headache. Impact of computerized tomography and cost-effectiveness. JAMA. 1980;243(4):359-62. [pmid: 6766193].
Lave JR, Pashos CL, Anderson GF, Brailer D, Bubolz T, Conrad D, Freund DA, Fox SH, Keeler E, Lipscomb J, et al. Costing medical care: using Medicare administrative data. Med Care. 1994;32:JS77-89. [pmid: 8028415].
Linet MS, Celentano DD, Stewart WF. Headache characteristics associated with physician consultation: a population-based survey. Am J Prev Med. 1991;7(1):40-6. [pmid: 1867898].
Linet MS, Stewart WF, Celentano DD, Ziegler D, Sprecher M. An epidemiologic study of headache among adolescents and young adults. JAMA. 1989;261(15):2211-6. [pmid: 2926969].
Lipton RB, Amatniek JC, Ferrari MD, Gross M. Migraine. Identifying and removing barriers to care. Neurology. 1994;44(6 Suppl 4):S63-8. [pmid: 8008228].
Lipton RB, Stewart WF. Migraine in the United States: a review of epidemiology and health care use. Neurology. 1993;43(6 Suppl 3):S6-10. [pmid: 8502385].
Lipton RB, Stewart WF, Celentano DD, Reed ML. Undiagnosed migraine headaches. A comparison of symptom-based and reported physician diagnosis. Arch Intern Med. 1992;152(6):1273-8. [pmid: 1599358].
Lipton RB, Stewart WF, Von Korff M. The burden of migraine. A review of cost to society. Pharmacoeconomics. 1994;6(3):215-21. [pmid: 10155264].
Lipton RB, Stewart WF, Von Korff M. Migraine impact and functional disability. Cephalalgia. 1995;15(Suppl 15):4-9. [pmid: 8749239].
Litaker DG, Solomon GD, Genzen JR. Impact of sumatriptan on clinic utilization and costs of care in migraineurs. Headache. 1996;36(9):538-41. [pmid: 8916561].
Luciani RJ, Osterhaus JT, Gutterman DL. Patient preferences for migraine therapy: subcutaneous sumatriptan compared with other medications. J Fam Pract. 1995;41(2):147-52. [pmid: 7636454].
MarketScan®. Databases [computerized database]. Ann Arbor MI. The MEDSTAT Group. 1998.
Mayou R, Seagroatt V, Goldacre M. Use of psychiatric services by patients in a general hospital. BMJ. 1991;303(6809):1029-32. [pmid: 1954454].
McGrath PJ, Humphreys P, Keene D, Goodman JT, Lascelles MA, Cunningham SJ, Firestone P. The efficacy and efficiency of a self-administered treatment for adolescent migraine. Pain. 1992;49(3):321-4. [pmid: 1408297].
Medical Economics Company. Drug topics redbook. Oradell, New Jersey. Medical Economics Co. 1996.
Michel P, Pariente P, Duru G, Dreyfus JP, Chabriat H, Henry P, Dreyfus JP. MIG ACCESS: a population-based, nationwide, comparative survey of access to care in migraine in France. Cephalalgia. 1996;16(1):50-5. [pmid: 8825700].
Micieli G, Frediani F, Cavallini A, Rossi F, Bussone G, Merli S, Nappi G. Quantification of headache disability: a diagnostic-based approach. Headache. 1995;35(3):131-7. [pmid: 7721572].
Mitchell CS, Osborn RE, Grosskreutz SR. Computed tomography in the headache patient: is routine evaluation really necessary?. Headache. 1993;33(2):82-6. [pmid: 8458727].
Mounstephen AH, Harrison RK. A study of migraine and its effects in a working population. Occup Med. 1995;45(6):311-7.
Murray WJ. Evaluation of aspirin in treatment of headache. Clin Pharmacol Ther. 1963;5(1):21-25. [pmid: 14107119].
Newland CA, Illis LS, Robinson PK, Batchelor BG, Waters WE. A survey of headache in an English city. Res Clin Stud Headache. 1978;5:1-20. [pmid: 674805].
Nuechterlein KH, Holroyd JC. Biofeedback in the treatment of tension headache. Current status. Arch Gen Psychiatry. 1980;37(8):866-73. [pmid: 6996634].
Osterhaus JT, Gutterman DL, Plachetka JR. Healthcare resource and lost labour costs of migraine headache in the US. Pharmacoeconomics. 1992;2(1):67-76. [pmid: 10146980].
Ottervanger JP, Valkenburg HA, Grobbee DE, Stricker BH. Pattern of sumatriptan use and overuse in general practice. Eur J Clin Pharmacol. 1996;50(5):353-5. [pmid: 8839655].
Pascual J, Polo JM, Berciano J. Serious migraine: a study of some epidemiological aspects. Headache. 1990;30(8):481-4. [pmid: 2228596].
Peters BH, Fraim CJ, Masel BE. Comparison of 650 mg aspirin and 1,000 mg acetaminophen with each other, and with placebo in moderately severe headache. Am J Med. 1983;74(6A):36-42. [pmid: 6344625].
Rapoport AM. Recurrent migraine: cost-effective care. Neurology. 1994;44(5 Suppl 3):S25-8. [pmid: 8202231].
Rasmussen BK, Jensen R, Olesen J. Impact of headache on sickness absence and utilisation of medical services: a Danish population study. J Epidemiol Community Health. 1992;46(4):443-6. [pmid: 1431724].
Richardson GM, McGrath PJ. Cognitive-behavioral therapy for migraine headaches: a minimal-therapist-contact approach versus a clinic-based approach. Headache. 1989;29(6):352-7. [pmid: 2759842].
Robinson RG. Pain relief for headaches. Is self-medication a problem. Can Fam Physician. 1993;39:867-8. [pmid: 8495144].
Saadah HA. Abortive headache therapy with intramuscular dihydroergotamine. Headache. 1992;32(1):18-20. [pmid: 1555927].
Sage MR, Wilson BC, Benness GT. Changes in neurological practice in South Australia after the introduction of computerized tomography. Med J Aust. 1980;1(4):163-5. [pmid: 7374547].
Salomone JA 3rd, Thomas RW, Althoff JR, Watson WA. An evaluation of the role of the ED in the management of migraine headaches. Am J Emerg Med. 1994;12(2):134-7. [pmid: 8161381].
Sands GH, Mulloy K, Goldstein J, Munoz E. Prospective payment experience with DRGs in headache patients. Headache. 1990;30(3):157-9. [pmid: 2108935].
Scarani G, Beghi E, Tognoni G. Pharmacological treatment of primary headache: analysis of current practice from a drug utilization study. Headache. 1987;27(6):345-50. [pmid: 3654192].
Siegel JE, Weinstein MC, Russell LB, Gold MR. Recommendations for reporting cost-effectiveness analyses. JAMA. 1996;276(16):1339-41. [pmid: 8861994].
Silberstein SD, Lipton RB. Headache epidemiology. Emphasis on migraine. Neurol Clin. 1996;14(2):421-34. [pmid: 8827180].
Silvestrini M, Bernardi G. Computed tomography in the routine evaluation of headache. Headache. 1994;34(3):176. [pmid: 8200795].
Sinclair DE, Kovacs G, Hillis M. Cranial CT scans—emergency department utilization. J Emerg Med. 1993;11(5):643-6. [pmid: 8308247].
Solomon GD. Quality-of-life assessment in patients with headache. Pharmacoeconomics. 1994;6(1):34-41. [pmid: 10147352].
Spencer DC, Daugird AJ. The nature and content of telephone prescribing habits in a community practice. Fam Med. 1990;22(3):205-9. [pmid: 2347448].
Stang PE, Osterhaus JT. Impact of migraine in the United States: data from the National Health Interview Survey. Headache. 1993;33(1):29-35. [pmid: 8436495].
Stang PE, Osterhaus JT, Celentano DD. Migraine. Patterns of healthcare use. Neurology. 1994;44(6 Suppl 4):S47-55. [pmid: 8008225].
Stang P, Sternfeld B, Sidney S. Migraine headache in a prepaid health plan: ascertainment, demographics, physiological, and behavioral factors. Headache. 1996;36(2):69-76. [pmid: 8742677].
Stang PE, Von Korff M. The diagnosis of headache in primary care: factors in the agreement of clinical and standardized diagnoses. Headache. 1994a;34(3):138-42. [pmid: 8200786].
Stang PE, Von Korff M. The stability of reported headache symptoms over time. Olesen J, editor. Headache classification and epidemiology. New York. Raven Press. 1994b:45-9.
Steiner TJ. Long-term cost-benefit assessment of anti-migraine drugs. Cephalalgia. 1995;15(Suppl 15):37-40. [pmid: 8749245].
Stewart WF, Lipton RB. The economic and social impact of migraine. Eur Neurol. 1994;34(Suppl 2):12-7. [pmid: 7835377].
Stewart WF, Lipton RB, Liberman J. Variation in migraine prevalence by race. Neurology. 1996;47(1):52-9. [pmid: 8710124].
Stewart WF, Lipton RB, Simon D. Work-related disability: results from the American migraine study. Cephalalgia. 1996;16(4):231-8. [pmid: 8792034].
Stewart WF, Shechter A, Liberman J. Physician consultation for headache pain and history of panic: results from a population-based study. Am J Med. 1992;92(1A):35S-40S. [pmid: 1734733].
Tansey MJ, Pilgrim AJ, Lloyd K. Sumatriptan in the acute treatment of migraine. J Neurol Sci. 1993;114(1):109-16. [pmid: 8381852].
Tfelt-Hansen P, Henry P, Mulder LJ, Scheldewaert RG, Schoenen J, Chazot G. The effectiveness of combined oral lysine acetylsalicylate and metoclopramide compared with oral sumatriptan for migraine. Lancet. 1995;346(8980):923-6. [pmid: 7564725].
To T, Wu K. Health care utilization and disability of migraine: the Ontario Health Survey. Can J Public Health. 1995;86(3):195-9. [pmid: 7671207].
Turkewitz LJ, Casaly JS, Dawson GA, Wirth O, Hurst RJ, Gillette PL. Self-administration of parenteral ketorolac tromethamine for head pain. Headache. 1992;32(9):452-4. [pmid: 1446989].
US Department of Health and Human Services. The International Classification of Diseases, 9th Revision, Clinical Modification. Fifth Edition. Reston (VA). U.S. Department of Health and Human Services, Public Health Service, Health Care Financing Administration. DHHS Publication No. (PHS) 94-1260. 1994.
van Roijen L, Essink-Bot ML, Koopmanschap MA, Michel BC, Rutten FF. Societal perspective on the burden of migraine in The Netherlands. Pharmacoeconomics. 1995;7(2):170-9. [pmid: 10155303].
Vernon HT. The effectiveness of chiropractic manipulation in the treatment of headache: an exploration in the literature. J Manipulative Physiol Ther. 1995;18(9):611-17. [pmid: 8775024].
Von Korff M, Galer BS, Stang P. Chronic use of symptomatic headache medications. Pain. 1995;62(2):179-186. [pmid: 8545143].
Von Korff M, Ormel J, Keefe FJ, Dworkin SF. Grading the severity of chronic pain. Pain. 1992;50(2):133-49. [pmid: 1408309].
Von Korff M, Stang P. Prediction of the psychosocial and behavorial outcomes of headache. Olesen J, editor. Headache classification and epidemiology. New York. Raven Press. 1994:367-71.
Von Korff M, Stewart WF, Lipton RB. Assessing headache severity. New directions. Neurology. 1994;44(6 Suppl 4):S40-6. [pmid: 8008224].
Von Korff M, Wagner EH, Dworkin SF, Saunders KW. Chronic pain and use of ambulatory health care. Psychosom Med. 1991;53(1):61-79. [pmid: 2011651].
Von Seggern RL, Adelman JU. Cost considerations in headache treatment. Part 2: Acute migraine treatment. Headache. 1996;36(8):493-502. [pmid: 8824005].
Weingarten S, Kleinman M, Elperin L, Larson EB. The effectiveness of cerebral imaging in the diagnosis of chronic headache. Arch Intern Med. 1992;152(12):2457-62. [pmid: 1456857].
Wilkinson M. Treatment of acute migraine: the British experience. Headache. 1990;30(Suppl 2):545-9. [pmid: 2125586].
Winnem J. Prevalence of adult migraine in general practice. Cephalalgia. 1992;12(5):300-3. [pmid: 1384985].
Yabroff KR, Schulman KA, Kong J, Rubenstein LE, Epstein AJ, Glick H. A health services approach for the evaluation of innovative pharmaceuticals and biotechnology products [abstract]. AHSR FHSR Annu Meet Abstr Book. no date. 12:125.
Yen S, McIntire RW. Operant therapy for constant headache complaints: a simple response-cost approach. Psychol Rep. 1971;28(1):267-70. [pmid: 5549447].
Ziegler DK, Paolo AM. Self-reported disability due to headache: a comparison of clinic patients and controls. Headache. 1996;36(8):476-80. [pmid: 8824002].