# Evidence Tables

Evidence Table 1 Health care provider consultation for chronic headache

Study | Dates and Methods | Headache Definition | Patient Population | N | Results
Clouse and Osterhaus, 1994 | 1/1/89–6/30/90 Retrospective claims review with matched control | ICD9 code 346 migraine headache | Patients enrolled in a United Health Care (UHC) Corporation-affiliated health plan. Age 18–64 with a UHC pharmacy benefit provision, at least one medical claim with ICD9 code = 346, and a pharmacy claim for a drug potentially used to treat migraine.^1^ The comparison had no migraine diagnosis, had at least one medical claim and were matched by age, sex, enrollment duration, and subscriber/dependent status. All subjects had a minimum 12-month enrollment. | N = 1,336 migraine N = 1,336 non-migraine controls | Medical and pharmacy costs for the migraine group were 64% greater than for the control group 1,201/1,336 (90%) of the migraine group had been seen by a physician for their migraine headaches These patients had 2,616 migraine related visits, averaging 2.2 visits per person
Edmeads Findlay, Tugwell, et al., 1993 | 4/89–4/90 Survey and diary | IHS migraine tension-type | [underlined: Prevalence Study]-Canadians age >15 were surveyed with random digit dialing. One respondent was selected per household; if there was more than one headache sufferer, then the one with the most recent birth date was chosen. [underlined: Interview Study]- 138 migraine and 83 tension-type respondents answered additional questions about their headaches. | Prevalence N = 1,573 Interview N =221 Diary N = 150 | [underlined: Prevalence Study] 64% of migraineurs had consulted a physician at some time for their headaches 45% of tension-type headache sufferers had consulted a physician at some time for their headaches 41 % of migraineurs who sought care were referred to a specialist 32% of tension-type headache sufferers who sought care were referred to a specialist [underlined: Interview Study] 81% of the migraineurs sought the care of a physician; of these 36% continued in follow-up 71 % of the tension-type headache sufferers sought the care of a physician; of these 28% continued in follow-up Reasons for discontinuing care included the availability of effective OTC medications, headaches of insufficient frequency or severity to continue receiving care, negative side effects of medications, or unhappiness with the physician
Green, 1977 | 1975–1976 Survey | Self-reported migraine | England: surveys distributed to people in managerial positions, members of Parliament, office and factory workers, school children, and bank and insurance agency employees. | N = 14,893 respondents | 19.44% of males and 25.72% of females responding reported that they suffered from migraine. If migraine was defined as unilateral headache then the prevalence dropped to 10.3% of males and 15.94% of females. 66.3% of males and 73.5% of females had consulted a physician about their headaches
Linet, Stewart, Celentano, et al., 1989 Migraine Prevalence Study (Washington County Study) | 3/86–6/87 Telephone survey and diary | Migraine^2^ | Washington County, Maryland residents age 12–29. Sample of all households with telephone. | N = 10,169 Not all subjects answered all questions | 6.5% of 4,033 males with migraine headache said they had consulted a physician in the last 12 months, 8.1% said they had consulted a physician but it was over 12 months ago, 85.4% said they had never consulted a physician for their headaches 15% of 4,857 females with migraine headache said they had consulted a physician in the last 12 months, 12.9% said they had consulted a physician but it was over 12 months ago, 72% said they had never consulted a physician for their headaches.
Lipton and Stewart, 1993 American Migraine Study^3^ | 11/88–12/88 Mail survey | IHS migraine | Representative sample of 15,000 US households. Obtained responses from 20,468 people age 12–80. | N = 2,422 | 38% of 2,479 severe migraine sufferers had received a physician diagnosis of migraine 41 % of women and 29% of men reported having been diagnosed Diagnosis was 40% more likely in people with an annual household income >$45,000 than in people with a household income of <$10,000 Women 30% more likely than men to be diagnosed Likelihood of diagnosis increased with age
Mounstephen and Harrison, 1995 | Dates unknown Survey | IHS migraine | Questionnaire distributed to a random sample of 476 employees of a chemical production and research facility. The sample was stratified by age and sex. The overall rate of work absence was validated by the company’s human resources database. There were 423 respondents to the questionnaire, 62 of the 423 were classified as having IHS migraine. | N = 62 | 42% of migraineurs said they had never consulted a physician for their headaches 19.4% of migraineurs said they had consulted a physician in the last year
Osterhaus, Gutterman, and Plachetka, 1992 | 1986–1991 Mail survey | IHS migraine | Patients previously enrolled in 1 of 2 clinical trials of a headache medication. Patients had been diagnosed by a physician as having migraine according to the IHS criteria. Patients were age 18 or over and had at least a 1-year history of migraine. | N = 648 | 585/648 (91%) had consulted a physician for their headaches Mean number of clinic visits was 6.32; 7.6% of the people who sought the care of a physician had greater than 12 physician visits 8% of the people seeing a physician accounted for 25% of the visits
Rasmussen, Jensen, and Olesen, 1992 | 1/89–7/89 Questionnaire Interview Physical examination | IHS migraine tension- type | Randomly selected people age 25–64 living in the western part of Copenhagen County (Denmark). | N =740 N = 119 migraine N =578 tension-type | 56% of migraineurs had consulted a general practitioner at some time for their headaches 16% of tension-type headache sufferers had consulted a general practitioner at some time for their headaches Consultation rate was higher among women than men For both migraine and tension-type headache there was a correlation between physician consultation and the frequency of headache 16/740 (2%) had ever been admitted to a hospital for attacks 16% of migraineurs and 4% of tension-type headache headache sufferers had consulted a specialist
Stang and Osterhaus, 1993 | 1989 Survey | Self- reported migraine | National Health Interview Survey | N = 116,929 respondents | Among those with self-reported migraine, 85% of women and 77% of men had ever sought the care of a physician for their headaches
van Roijen, Essink-Bot, Koopmanschap, et al., 1995 | 10/92 (interview) 6/93 (survey) Interview/survey | IHS migraine migraine + tension-type | Representative sample of the Dutch population age 12 years and older. Questioned 10,480 people in face-to-face interviews; of these, 992 met IHS criteria, had had a headache attack in the last 12 months, and agreed to participate. | N = 436 headache sufferers responded to the survey N = 585 non-headache controls | 70% of migraine patients consulted a physician for their headaches (lifetime) Average 1.3 consultations per year per patient 6% saw a neurologist 17% sought alternative practitioners

Abbreviations: ICD9 = International Classification of Diseases, 9th Revision; IHS = International Headache Society; OTC = over-the-counter; US = United States

1 Potential medications included: ergot alkaloids, Esgic®, Fiorinal®, isometheptene, methysergide, Phrenillin®, narcotic analgesics, NSAIDs, antidepressants, calcium antagonists, and beta-blockers.

2 Data collection on this study began prior to the release by the Ad Hoc Committee of its new definition of migraine. Study questions were not revised to reflect the new definition.

3 This publication includes data from both the American Migraine Study and the Migraine Prevalence Study. Only medication results from the American Migraine Study are presented in this paper and in this table.

Evidence Table 2 Emergency department (ED) utilization for treatment of chronic headache

Study | Dates and Methods | Headache Definition | Patient Population | N | Results
Celentano, Stewart, Lipton, et al., 1992 American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | Representative sample of 15,000 US households. Obtained responses from 20,468 people age 12–18. | N = 2,422 | 13% of males and 19.5% of females reported using the ED for treatment of their headaches at some point Rate of ED use varied by the type of medication used by the patient 27% of males and 33% of females taking prescription drugs used the ED. This was three times the rate among non-prescription drug users.
Clouse and Osterhaus, 1994 | 1/1/89–6/30/90 Retro- spective claims review with matched control | ICD9 code 346 migraine headache | Patients enrolled in a United Health Care Corporation (UHC) affiliated health plan. Age 18–64 with a UHC pharmacy benefit provision, at least one medical claim with ICD9 code=346, and a pharmacy claim for a drug potentially used to treat migraine.^1^ The comparison group had no migraine diagnosis, had at least one medical claim, and were matched by age, gender, enrollment duration, and subscriber/dependent status. All subjects had a minimum 12-month enrollment. | N = 1,336 migraine N = 1,336 non-migraine controls | 238/1336 migraine patients used the ED for treatment of their migraine headaches. These 238 patients had a total of 700 visits to the ED. An additional 293 visits were made by 118/1336 migraine patients to the ED for the treatment of non-migraine headache.^2^
Edmeads, Findlay, Tugwell, et al., 1993 | 4/89–4/90 Survey and diary | IHS migraine tension- type | Canadians age>15 were surveyed with random digit dialing. One respondent was selected per household; if there was more than one headache sufferer, then the one with the most recent birth date was chosen. | N = 1,573 | 14% of migraineurs and 8% of tension-type headache sufferers had sought care in the ED
Linet, Stewart, Celentano, et al., 1989 Migraine Prevalence (Washington Study County Study) | 3/86–6/87 Telephone survey and diary | migraine^3^ | Washington County, Maryland residents age 12–29. Sample of all households with a telephone. | N = 10,169 Not all subjects answered all questions | 5.32% of males and 3.4% of females had seen a physician in the ED for their headaches in the last 12 months
Michel, Pariente, Duru, et al., 1996 | Dates unknown Survey | IHS migraine | Used a “poll-base” to screen 6,000 French households for adults (≥18 yrs) who met cirtieria for IHS migraine in the previous 3 months. Mailed a questionnaire with a variety of health-related questions, not pertaining to migraine. A second survey was sent to a group who screened positively for migraine and to a matched controlled group without migraine. | N = 478 migraine N = 525 controls | In the previous 6 months, 5% of migraineurs and 6% of controls had been seen in the ED (difference not significant).
Osterhaus, Gutterman, and Plachetka, 1992 | 1986–1991 Mail survey | IHS migraine | Patients previously enrolled in 1 of 2 clinical trials of a headache medication. Patients had been diagnosed by a physician as having migraine according to the IHS criteria. Patients were age 18 or over and had at least a 1-year history of migraine. | N =648 | 308/648 (48%) had used the ED for treatment of their headaches 22% of people using the ED had 1–2 visits, 15% had more than 5 visits; and 15% of the ED users accounted for 60% of all visits.

Abbreviations: ED = emergency department; ICD9 = International Classification of Diseases, 9th Revision; IHS = International Headache Society; US =United States

1 Potential medications included: ergot alkaloids, Esgic®, Fiorinal®, isometheptene, methysergide, Phrenilln®, narcotic analgesics, NSAIDs. antidepressants, calcium antagonists, and beta-blockers.

2 Study does not indicate the overlap between groups seeking care in the Emergency Department for migraine and non-migraine headaches.

3 Data collection on this study began prior to the release by the Ad Hoc Committee of its new definition of migraine. Study questions were not revised to reflect the new definition.

Evidence Table 3 Hospital admission for treatment of chronic headache

Study | Dates and Methods | Headache Definition | Patient Population | N | Results
Clouse and Osterhaus, 1994 | 1/1/89–6/30/90 Retrospective claims review with matched control group | ICD code 346 migraine headache | Patients enrolled in a United Health Care Corporation (UHC) affiliated health plan. Age 18–64 with a UHC pharmacy benefit provision, at least one medical claim with ICD9 code=346, and a pharmacy claim for a drug potentially used to treat migraine.^1^ The comparison group had no migraine diagnosis, had at least one medical claim, and was matched by age, sex, enrollment duration, and subscriber/dependent status. All subjects had a minimum 12-month enrollment. | N = 1,336 migraine N = 1,336 non-migraine controls | 142/1336 (11%) of migraineurs were hospitalized in the study period for their headaches. This group had 306 hospitalizations.
Michel, Pariente, Duru, et al., 1996 | Dates unknown Survey | IHS migraine | Used a “poll-base” to screen 6,000 French households for adults (≥ 18 yrs) who met cirtieria for IHS migraine in the previous 3 months. Mailed a questionnaire with a variety of health-related questions, not pertaining to migraine. A second survey was sent to a group who screened positively for migraine and to a matched controlled group without migraine. | N = 478 migraine N = 525 controls | In the previous 6 months, 7% of migraineurs and 8% of controls had been hospitalized.
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 | IHS migraine tension- type cluster | Patients recruited from the Headache Research Centers of the Neurological Institute of the University of Pavia and the University of Milan (Italy). Patients were referred from general practice (70%) and self referred (30%). | N = 400 | Lifetime Utilization of Hospital Resources:
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 | IHS migraine tension- type cluster | | N = 400 | | Episodic HA (including migraine) | Chronic tension-type HA | Mixed migraine + tension-type HA
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 | IHS migraine tension- type cluster | | N = 400 | Mean # of hospital admissions | 0.1 | 0.3 | 0.1
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 | IHS migraine tension- type cluster | | N = 400 | Mean # of days in hospital | 0.8 | 4.8 | 0.7
Osterhaus, Gutterman, and Plachetka, 1992 | 1986–1991 Mail survey | IHS migraine | Patients previously enrolled in 1 of 2 clinical trials of a headache medication. Patients had been diagnosed by a physician as having migraine according to the IHS criteria. Patients were age 18 or over and had at least a 1-year history of migraine. | N = 648 | 43/648 (7%) had been hospitalized for treatment of their headaches.
Rasmussen, Jensen, and Olesen, 1992 | 1/89–7/89 Questionnaire Interview Physical examination | IHS migraine tension- type cluster | Randomly selected people age 25–64 living in the western part of Copenhagen County (Denmark). | N =740 (total) N = 119 migraine N =578 tension-type | 16/740 (2%) had ever been admitted to a hospital for a headache.
Stang and Osterhaus, 1993 | 1989 Survey | Self- reported migraine | National Health Interview Study | N = 116,929 respondents | 6.2% of males and 8.4% of females had been hospitalized for the treatment of their headaches during their lifetime.

Abbreviations: HA = headache; ICD9 = International Classification of Diseases, 9th Revision; IHS = International Headache Society

1 Potential medications included: ergot alkaloids, Esgic®, Fiorinal®, isometheptene, methysergide, Phrenilin®, narcotic analgesics, NSAIDs, antidepressants, calcium antagonists, and beta-blockers.

Evidence Table 4 Use of pharmaceutical agents in the treatment of chronic headache

Study | Dates and Methods | Headache Definition | Population Inclusion Criteria | Sample Size | Results
Celentano, Stewart, Lipton, et al., 1992 American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | Representative sample of 15,000 US households. Obtained responses from 20,468 people age 12–80. | N = 2,422 | Statistically significant difference by sex (P<0.001) in the use of prescription medications Migraineurs reported an 80% greater use of prescription medication than subjects with “severe headache” 4.2% of males and 2.9% of females reported no medication use for their headaches Black migraineurs reported considerably less prescription medication use than whites Black females were less likely than white women or women from other racial groups to treat their headaches or to use prescription medications. Use of prescription medication increased with age; increasing from 26.0% of men <30 to 38.6% from 50–59. Prescription medication use increased among women from 32.9% at <30 to 44.9% at 50–59. Migraineurs with incomes < $20,000 were less likely than those with higher incomes to use prescription meds (but not significantly so). Rates of prescription use were highest in the Mountain Region and New England states ·and lowest in Atlantic and North Central Regions 52.3% of women and 38.3% of men with vomiting used prescription medications. 48.1 % of women and 30.2% of men with visual aura used prescription medications. Level of disability was also related to prescription use, as was duration of attack.
Clarke, MacMillan, Sondhi, et al., 1996 | 5/94–6/94 Survey | IHS migraine | Questionnaire mailed to 4,200 employees of the Royal Hull Hospitals Trust (UK). Of the 1,903 surveys returned, 158 (8.3%) were classified as having migraine. | N = 158 | 28% used prescription medications, 78% used OTCs 4/158 said they used sumatriptan 8/158 said they were using prophylactic treatment (either propranolol or pizotifen) 13% used alternative therapies such as acupuncture, homeopathy, or yoga
Edmeads, Findlay, Tugwell, et al., 1993 | 4/89–4/90 Survey and diary | IHS migraine and tension-type | Prevalence Study-Canadians age 15+ were surveyed with random digit dialing. One respondent was selected per household. If there was more than one headache sufferer then the one with the most recent birth date was chosen. | Prevalence N = 1,573 | Prevalence study: Migraineurs- 44% used prescription medication, 91% non-prescription medication, 48% non-medical treatments, 6% preventive medications Tension-type headache sufferers-24% used prescription medications, 90% non-prescription medications, 34% non-medical treatments, 3% preventive medications In the interview study prescription medications were prescribed for 62% of those who had seen a physician; at the time of the interview 34% continued to use them. Non-prescription medications recommended for 50%; 25% of these people discontinued treatment. 63% of those interviewed who had never seen a physician also used medication; and 10% of these people who had never seen a physician for their headaches were using prescription medications. Migraine: 19% of headaches completely relieved by medication 62% of headaches partially relieved by medication Tension-type headaches: 43% of headaches completely relieved by medication 47% of headaches partially relieved by medication Migraine and tension-type headache sufferers used medications an average of 3 times per week. 21% of migraineurs and 17% of tension-type headache sufferers used medications more than one time per week
Kryst and Scherl, 1994 | Spring 1990 Telephone survey | Modified IHS migraine | Study question included as part of the Kentucky Health Survey. Sample households contacted through random digit dialing. Data only primary respondents only included as part of this analysis. | N =55 migraine N =32 serious non-migraine HA | 82/87 (94.3%) of serious headache sufferers reported taking medication in the last year 41/82 (50%) used OTC and 35/82 (42.7%) prescription, 6/82 (7.3%) both 29/64 (45.3%) of headache sufferers who reported disabilities took only OTCs Interference with family relations was strongly associated with use of prescription medication (P=0.05) Use of prescription drugs was not related to income level or insurance coverage for prescription medications
Linet, Stewart, Celentano, et al., 1989 Migraine Prevalence Study (Washington County Study) | 3/86–6/87 Telephone interview and diary study | Migraine | Washington County, Maryland residents 12–29 years old. Sample of all households with telephone. | N = 10,169 Not all subjects answered all questions | [underlined: Age] | [underlined: 12–17] | [underlined: 18–23] | [underlined: 24–29]
Linet, Stewart, Celentano, et al., 1989 Migraine Prevalence Study (Washington County Study) | 3/86–6/87 Telephone interview and diary study | Migraine | Washington County, Maryland residents 12–29 years old. Sample of all households with telephone. | N = 10,169 Not all subjects answered all questions | Males | 8.8% | 16.2% | 18.0%
Linet, Stewart, Celentano, et al., 1989 Migraine Prevalence Study (Washington County Study) | 3/86–6/87 Telephone interview and diary study | Migraine | Washington County, Maryland residents 12–29 years old. Sample of all households with telephone. | N = 10,169 Not all subjects answered all questions | Females | 10.9% | 16.8%
Linet, Stewart, Celentano, et al., 1989 Migraine Prevalence Study (Washington County Study) | 3/86–6/87 Telephone interview and diary study | Migraine | Washington County, Maryland residents 12–29 years old. Sample of all households with telephone. | N = 10,169 Not all subjects answered all questions | Among males, approximately twice as many in the older age groups had taken at least one prescription medication in the last 12 months than in the youngest age groups. Among females prescription drug use also increased with age.
Lipton and Stewart, 1993 | 11/88–12/88 Mail survey | IHS migraine | Representative sample of 15,000 US households. Obtained responses from 20,468 people age 12–80. | N = 2,422 | 95% of severe migraineurs have used some type of medication Most migraineurs take non-prescription medications rather than prescription Among women, 56.8% used non-prescription medications, 40.1% used prescription drugs, and 3.1 % take no medications for their headaches Among men, 66.9% used non-prescription medications, 28.3% used prescription drugs, and 4.8% take no medications for their headaches 43% of men and 34% of women with 3+ headaches per month do not use prescription medication 61 % of men and 47% of women with moderate or severe headache related disability do not use prescription medications
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | Patients recruited from the Headache Research Centers of the Neurological Institute of the University of Pavia and the University of Milan. 70% had been referred from general practice and 30% were self referred. | N =400 | Headache Characteristics and Response to Therapy:
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | | [underlined: Total] | [underlined: Episodic HA (including migraine)] | [underlined: Mixed migraine + tension-type HA] | [underlined: Chronic tension-type]
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | [underlined: HA]
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | [underlined: Analgesic consumption]
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | None | 7.5% | 6.9 | 8.7 | 7.7
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | Monthly | 28.0 | 33.5 | 17.4 | 5.8
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | Weekly | 46.6 | 49.0 | 47.8 | 36.5
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | Daily | 12.7 | 8.6 | 17.4 | 30.8
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | More than 1/day | 5.3 | 2.0 | 8.7 | 19.2
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | [underlined: Analgesic efficacy]
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | None | 6.4 | 6.6 | 4.8 | 6.3
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | Fair | 44.3 | 39.5 | 57.1 | 60.4
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | Good | 49.3 | 53.9 | 38.1 | 33.3
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | [underlined: Preventive therapy]
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | None | 46.8 | 47.9 | 50.0 | 45.5
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | Fair | 31.2 | 25.0 | 25.0 | 40.9
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | | N =400 | Good | 22.1 | 27.1 | 25.0 | 13.6
Mountstephen and Harrison, 1995 | Dates unknown Survey | IHS migraine | Questionnaire distributed to a random sample of 476 employees of a chemical production and research facility. The sample was stratified by age and sex. The overall rate of work absence was validated by the company’s human resources database. There were 423 respondents to the questionnaire; 62 of the 423 were classified as having IHS migraine. | N =62 | 10% of migraineurs obtained their medication by prescription 13% used prophylactic medication
Rasmussen, Jensen, and Olesen, 1992 | 1/89–7/89 Questionnaire Interview Physical examination | IHS migraine and tension-type | Randomly selected people, 25–64 years old, living in the western part of Copenhagen county (Denmark). | N =740 | 38/77 (49%) with migraine in the previous year used medication in the current year 480/549 (87%) with tension-type headache in the previous year used medication in the current year 31% of migraine and 59% of tension-type headache sufferers used medications with acetylsalicylic acid an average of 1–3 times a month. Significant correlation between frequency of headache and medication use 17% of migraineurs used ergotamine or dihydroergotamine agents 1–3 times per month 7% used preventive treatment (4% beta-blockers and 3% clonidine)
Von Korff, Galer, and Stang, 1995 | 1989–1990 Questionnaire | IHS migraine | Patients making headache related visits to primary care provider at Group Health of Puget Sound. Patients were 18–75 years old and had to be continuously enrolled for one year. Patients were excluded if they planned to disenroll or if they did not have a telephone. | N =662 | Percent of headache patients reporting frequent medication use in the previous month:
Von Korff, Galer, and Stang, 1995 | 1989–1990 Questionnaire | IHS migraine | | N =662 | | [underlined: Baseline] | [underlined: One year] | [underlined: Two years] | [underlined: Chronic]
Von Korff, Galer, and Stang, 1995 | 1989–1990 Questionnaire | IHS migraine | | N =662 | Prescription | 18.4% | 10.3 | 10.1 | 7.7
Von Korff, Galer, and Stang, 1995 | 1989–1990 Questionnaire | IHS migraine | | N =662 | Non-Prescription | 20.1 | 19.0 | 17.7 | 15.9
Von Korff, Galer, and Stang, 1995 | 1989–1990 Questionnaire | IHS migraine | | N =662 | Poly Pharmacy | 5.6 | 4.7 | 3.6 | 2.6

Abbreviations: HA =headache; IHS =International Headache Society; NA =not available; OTC =over-the-counter; UK =United Kingdom; US =United States

Evidence Table 5 Cost-effectiveness of non-pharmacological treatments for chronic headache

Study | Study Design | Headache Definition | Patient Population | Number of patients; Interventions | Results
Attanasio, Andrasik, and Blanchard, 1987 | Prospective Randomized | Ad Hoc tension-type | Patients recruited from a university based headache clinic. | N = 25 (total) Relaxation + cognitive-behavioral therapy (office-based) (N = 7) Relaxation + cognitive-behavioral therapy (home-based) (N = 8) Relaxation only (home-based) (N = 6) | No effect of treatment was seen. There was no significant difference in cost effectiveness between treatment groups.
Blanchard, Andrasik, Appelbaum, et al., 1985 Study 1 | Prospective Randomized | Ad Hoc tension-type | Does not describe the setting in which patients were recruited. No inclusion or exclusion criteria. | N =53 Relaxation + thermal biofeedback: Clinic-based (N = 26) Home-based (N = 27) | Both interventions had significant reduction in headache activity from baseline but were not significantly different from each other. The home-based intervention was much more cost-effective than clinic-based treatment (P=0.009).
Blanchard, Andrasik, Appelbaum, et al., 1985 Study 2 | Prospective Randomized | Ad Hoc migraine mixed migraine and tension-type | Does not describe the setting in which the patients were recruited. No inclusion or exclusion criteria. | N = 39 (migraine) Relaxation + thermal biofeedback: Clinic-based (N = 21) Home-based (N = 18) N = 48 mixed migraine and tension-type Relaxation + thermal biofeedback: Clinic-based (N = 22) Home-based (N = 26) | Both interventions led to significant reductions in headache activity but they were not significantly different from each other. The home-based intervention was 4 times more cost effective for migraine (P<0.001) and 6 times more cost effective for mixed migraine + tension-type headache than clinic-based treatment.
Blanchard, Jaccard, Andrasik, et al., 1985 | Retrospective '81–'82 Prospective '83–'84 | Chronic headache: migraine tension-type mixed migraine/tension-type | Does not describe the setting in which the patients were recruited. No inclusion or exclusion criteria. | N =73 Various combinations of relaxation and biofeedback training | Two-year medical costs associated with chronic headache before and after treatment.
Blanchard, Jaccard, Andrasik, et al., 1985 | Retrospective '81–'82 Prospective '83–'84 | Chronic headache: migraine tension-type mixed migraine/tension-type | Does not describe the setting in which the patients were recruited. No inclusion or exclusion criteria. | N =73 Various combinations of relaxation and biofeedback training | [underlined: Category] | [underlined: Mean Pre-tx] | [underlined: Mean Post-tx]
Blanchard, Jaccard, Andrasik, et al., 1985 | Retrospective '81–'82 Prospective '83–'84 | Chronic headache: migraine tension-type mixed migraine/tension-type | Does not describe the setting in which the patients were recruited. No inclusion or exclusion criteria. | N =73 Various combinations of relaxation and biofeedback training | Medication | $225 | $33
Blanchard, Jaccard, Andrasik, et al., 1985 | Retrospective '81–'82 Prospective '83–'84 | Chronic headache: migraine tension-type mixed migraine/tension-type | Does not describe the setting in which the patients were recruited. No inclusion or exclusion criteria. | N =73 Various combinations of relaxation and biofeedback training | FP visits | 80 | 15
Blanchard, Jaccard, Andrasik, et al., 1985 | Retrospective '81–'82 Prospective '83–'84 | Chronic headache: migraine tension-type mixed migraine/tension-type | Does not describe the setting in which the patients were recruited. No inclusion or exclusion criteria. | N =73 Various combinations of relaxation and biofeedback training | Neuro visits | 275 | NA
Blanchard, Jaccard, Andrasik, et al., 1985 | Retrospective '81–'82 Prospective '83–'84 | Chronic headache: migraine tension-type mixed migraine/tension-type | Does not describe the setting in which the patients were recruited. No inclusion or exclusion criteria. | N =73 Various combinations of relaxation and biofeedback training | Hospital | 211 | 3
Blanchard, Jaccard, Andrasik, et al., 1985 | Retrospective '81–'82 Prospective '83–'84 | Chronic headache: migraine tension-type mixed migraine/tension-type | Does not describe the setting in which the patients were recruited. No inclusion or exclusion criteria. | N =73 Various combinations of relaxation and biofeedback training | Non-med | 164 | 2
Blanchard, Jaccard, Andrasik, et al., 1985 | Retrospective '81–'82 Prospective '83–'84 | Chronic headache: migraine tension-type mixed migraine/tension-type | Does not describe the setting in which the patients were recruited. No inclusion or exclusion criteria. | N =73 Various combinations of relaxation and biofeedback training | Total | 995 | 52

Abbreviations: tx =treatment

Evidence Table 6 Work loss due to chronic headache

Study | Dates and Methods | Headache Definition | Patient Population | N | Results
Celentano, Stewart, Lipton, et al., 1992 American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | Representative sample of 15,000 US households. Obtained responses from 20,468 people age 12–80. | N =2,422 | Headache Related Disability:
Celentano, Stewart, Lipton, et al., 1992 American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | Representative sample of 15,000 US households. Obtained responses from 20,468 people age 12–80. | N =2,422 | | [underlined: Males] | [underlined: Females]
Celentano, Stewart, Lipton, et al., 1992 American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | Representative sample of 15,000 US households. Obtained responses from 20,468 people age 12–80. | N =2,422 | None | 15.3% | 11.2
Celentano, Stewart, Lipton, et al., 1992 American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | Representative sample of 15,000 US households. Obtained responses from 20,468 people age 12–80. | N =2,422 | Mild | 53.0 | 50.8
Celentano, Stewart, Lipton, et al., 1992 American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | Representative sample of 15,000 US households. Obtained responses from 20,468 people age 12–80. | N =2,422 | Mod/Sev | 30.7 | 36.9
Celentano, Stewart, Lipton, et al., 1992 American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | Representative sample of 15,000 US households. Obtained responses from 20,468 people age 12–80. | N =2,422 | Don’t Know | 1.0 | 1.1
Celentano, Stewart, Lipton, et al., 1992 American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | Representative sample of 15,000 US households. Obtained responses from 20,468 people age 12–80. | N =2,422 | As disability level increased, prescription medication used increased Moderate or severe disability was defined as the need for bed rest, absence from work or school, and inability to do usual activities
Clarke, MacMillan, Sondhi, et al., 1996 | 5/94–6/94 | IHS migraine | Questionnaire mailed to 4,200 employees of the Royal Hull Hospitals Trust (UK). Of 1,903 surveys returned 158 (8.3%) were migraine. | N =158 | 76% reported no time lost from work, 13% were absent one day, 6% two days, 6% three to five days, and 1% reported being absent more than six days The mean absence rate was 0.49 days per month or 2 days per year Employees with migraine spent 15.5 days per year at work with an attack, and were only 56% effective for an equivalent of 5.5 additional days of work lost An average of two days’ absence per year due to headache would be equivalent to about 20% of all the sickness related absence in the NHS
Edmeads, Findlay, Tugwell, et. al., 1993 | 4/89–4/90 Survey and diary | IHS migraine tension- type | [underlined: Diarv Study]—done 3 months after Prevalence and Interview studies (1/90–3/90). 95 migraine and 55 tension-type headache sufferers completed diaries about their headaches. | Diary N = 150 | 11% of the migraine and 4% of tension-type headache occurrences caused the person to leave or not attend work
Green, 1977 | 1975–1976 Survey | Self-reported migraine | England: surveys distributed to people in managerial positions, members of Parliament, office and factory workers, school children, and bank and insurance agency employees. | N = 14,893 respondents | Just over 1/3 of males and just under 1/3 of females said they were never absent from work due to migraine Migraineurs were absent from work approximately 4 days/year due to headache
Jones and Harrop, 1980 | 8/79 Survey | Self-reported migraine | Employees of General Foods Ltd. (UK). Surveyed 2,100 employees, 895 responses returned. Of the 895, 20% reported migraine at some time. | N =895 respondents | Over 8 months, 98 employees lost 281 work days due to migraine Mean number of days absent, 2.87; extrapolated to 1 year, the mean number of days lost would be 4.30 36/111 migraine attacks during the study period occurred at work
Kryst and Scherl, 1994 | Spring 1990 Telephone survey | Modified IHS migraine | Study questions included as part of the Kentucky Health Survey. Sample households contacted through random digit dialing. Data on only primary respondents included as part of this analysis. | N = 55 migraine N = 32 serious non-migraine | 56.3% reported that headache affected their ability to work efficiently (outside or inside the home) 37.9% reported that headache affected their attendance at work or school Many respondents continued to attend work or school even though they had a headache
Linet, Stewart, Celentano, et al., 1989 Migraine Prevalence Study (Washington County Study) | 3/86–6/87 Telephone survey and diary | Migraine^1^ | Washington County, Maryland residents age 12–29. Sample of all households with telephone. | N=10,169 Not all subjects answered all questions | Work or school missed:
Linet, Stewart, Celentano, et al., 1989 Migraine Prevalence Study (Washington County Study) | 3/86–6/87 Telephone survey and diary | Migraine^1^ | Washington County, Maryland residents age 12–29. Sample of all households with telephone. | N=10,169 Not all subjects answered all questions | | Men | Women
Linet, Stewart, Celentano, et al., 1989 Migraine Prevalence Study (Washington County Study) | 3/86–6/87 Telephone survey and diary | Migraine^1^ | Washington County, Maryland residents age 12–29. Sample of all households with telephone. | N=10,169 Not all subjects answered all questions | None | 91.7% | 85.9
Linet, Stewart, Celentano, et al., 1989 Migraine Prevalence Study (Washington County Study) | 3/86–6/87 Telephone survey and diary | Migraine^1^ | Washington County, Maryland residents age 12–29. Sample of all households with telephone. | N=10,169 Not all subjects answered all questions | 1/2 day | 6.1 | 10.2
Linet, Stewart, Celentano, et al., 1989 Migraine Prevalence Study (Washington County Study) | 3/86–6/87 Telephone survey and diary | Migraine^1^ | Washington County, Maryland residents age 12–29. Sample of all households with telephone. | N=10,169 Not all subjects answered all questions | all day | 1.8 | 3.7
Linet, Stewart, Celentano, et al., 1989 Migraine Prevalence Study (Washington County Study) | 3/86–6/87 Telephone survey and diary | Migraine^1^ | Washington County, Maryland residents age 12–29. Sample of all households with telephone. | N=10,169 Not all subjects answered all questions | missing | 0.4 | 0.2
Linet, Stewart, Celentano, et al., 1989 Migraine Prevalence Study (Washington County Study) | 3/86–6/87 Telephone survey and diary | Migraine^1^ | Washington County, Maryland residents age 12–29. Sample of all households with telephone. | N=10,169 Not all subjects answered all questions | Disability was most pronounced among women ages 24–29; this was the least affected age group in males
Micieli, Frediani, Cavallini, et al., 1995 | 1/90–1/91 Interview | IHS migraine tension-type cluster | Patients recruited from the Headache Research Centers of the Neurological Institute of the University of Pavia and the University of Milan (Italy). 70% had been referred from general practice and 30% were self referred. | N =400 | Headache during work hours was reported to be completely disabling by 58.5% episodic headache patients, 70.6% of chronic tension-type headache patients, and 30.4% of migraine + tension-type headache patients Missed work days per month 5.1 for episodic headache patients, 3.7 for chronic tension-type headache patients, 2.4 for mixed migraine + tension-type headache patients
Mounstephen and Harrison, 1995 | Dates unknown Survey | IHS migraine | Questionnaire distributed to a random sample of 476 employees of a chemical production and research facility. The sample was stratified by age and sex. The overall rate of work absence was validated by the company’s human resources database. There were 423 respondents to the questionnaire, 62 of the 423 were classified as having IHS migraine. | N = 62 | Based on the duration and frequency of migraine attacks, the authors calculated that women would experience 144 hours of headache per year and men 44 hours. Some of these hours would be during work, but they did not collect this information specifically.
Newland, Illis, Robinson, et al., 1978 | 7/73–2/74 Mail survey | Self-reported headache | Population based sample in Southampton, England | N = 2,066 respondents | Among 655 men reporting any headache in the past year, 42 (6%) reported work loss averaging 3.7 days. All work loss occurred among men reporting headaches associated with at least one feature of migraine (unilateral distribution, warning, or nausea).
Osterhaus, Gutterman, and Plachetka, 1992 | 1986–1991 Mail survey | IHS migraine | Patients previously enrolled in 1 of 2 clinical trials of a headache medication. Patients had been diagnosed by a physician as having migraine according to the IHS criteria. Patients were age 18 or over and had at least a 1-year history of migraine. | N = 648 | 29/56 males reported missing work in 1 month, they were absent an average of 2.5 days per month 250/445 females reported missing work in 1 month, they were absent an average of 2.1 days per month 55/56 men reported reduced work effectiveness; 60% as effective 430/445 women reported reduced work effectiveness; 56.3% as effective Of the 56% of employed respondents who reported missing work due to headache, a mean of 2.2 work days were missed Employed respondents worked an average of 5.8 days with migraine in the previous month Annual cost of lost labor (including benefits) men: $6,864 and $3,600 for women
Rasmussen, Jensen, and Olesen, 1992 | 1/89–7/89 Questionnaire Interview Physical examination | IHS migraine tension-type | Randomly selected people age 25–64 living in the western part of Copenhagen County (Denmark). | N = 740 N = 119 migraine N = 578 tension-type | 29/67 (43%) of gainfully employed migraineurs said they had been absent from work at least one time in the last year due to headache 91 % were absent less than 7 days, but 9% said they were absent 7–14 days 56/472 (12%) of tension-type headache sufferers said they had been absent from work at least one time in the last year due to headache 16% said they were absent more than 14 days Women had a higher absence rate than men, but not significantly so Absence rate among migraineurs was significantly higher than among tension-type headache sufferers
Stang and Osterhaus, 1993 | 1989 Survey | self-reported migraine | National Health Interview Survey | N = 116,929 respondents | Estimated 825,916 restricted activity days per 2 weeks among employed persons or 3.465 restricted activity days per migraineur per year Estimate that housewives lose 38.5 million days of activity per year Based on wages lost, they calculated that the 6,196,378 employed migraineurs lost 1.4 billion dollars per year
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | Households contacted through random digit dialing. Subjects were eligible if age 18–65. Respondents were included if they had at least one headache which was not attributable to injury, hangover, pregnancy, or cold or flu. | N = 1,775 migraine | [underlined: Women]
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | | | [underlined: White] | [underlined: Black] | [underlined: Asian-American]
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | missed work or school: | never | 32.7% | 34.3 | 57.1
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | missed work or school: | rarely | 30.9 | 30.4 | 14.3
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | missed work or school: | 1/2 the time | 16.3 | 13.1 | 14.3
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | missed work or school: | ≥ 1/2 the time | 20.1 | 22.3 | 14.3
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | % reduced work efficiency | none | 7.3 | 14.6 | 16.7
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | % reduced work efficiency | <25% | 22.8 | 20.5 | 16.7
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | % reduced work efficiency | 25–49% | 35.4 | 35.4 | 0.0
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | % reduced work efficiency | 50–74% | 17.6 | 11.9 | 50.0
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | % reduced work efficiency | ≥ 75% | 16.9 | 17.6 | 16.7
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | [underlined: Men]
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | | | [underlined: White] | [underlined: Black] | [underlined: Asian-American]
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | missed work or school: | never | 43.4 | 42.4 | 0.0
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | missed work or school: | rarely | 31.6 | 27.3 | 66.7
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | missed work or school: | 1/2 the time | 8.9 | 19.7 | 0.0
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | missed work or school: | ≥ 1/2 the time | 16.1 | 10.6 | 33.3
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | % reduced work efficiency | none | 9.2 | 17.7 | 0.0
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | % reduced work efficiency | <25% | 23.7 | 19.4 | 0.0
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | % reduced work efficiency | 25–49% | 36.5 | 37.1 | 50.0
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | % reduced work efficiency | ≥ 75% | 15.8 | 21.0 | 0.0
Stewart, Lipton, and Liberman, 1996 Baltimore County Study | 11/93–8/94 Telephone survey | IHS migraine | | N = 1,775 migraine | No difference was seen by race in frequency of missed work or duration of attack Black women reported more frequent attacks but were significantly less likely to report reduced efficiency at work Black men were also less likely to report reduced efficiency
Stewart, Lipton, and Simon, 1996 Follow-up to American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | The first American Migraine Study survey was mailed to a representative sample of 15,000 households. A total of 20,468 individuals age 12–80 responded. Using IHS criteria and data from that survey, 2,355 people age 18 or over with one or more migraine attacks in the previous year were identified. A second survey, the "Headache Disability and Healthcare Questionnaire," was sent to these individuals during the 12 months covered by the original survey. | N = 1,663 | Median number of missed workdays was 1 for men and 2 for women. Average number of missed workdays was 3.8 for men and 8.3 for women. At least one day of work was missed in the last year by 56.4% of men and 73.6% of women. Men reported 42% effectiveness at work; women 34%. Lost work day equivalents (LWDE):
Stewart, Lipton, and Simon, 1996 Follow-up to American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | | N = 1,663 | | [underlined: LWDE] | [underlined: Men] | [underlined: Women]
Stewart, Lipton, and Simon, 1996 Follow-up to American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | | N = 1,663 | | 0 | 6.1% | 12.0%
Stewart, Lipton, and Simon, 1996 Follow-up to American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | | N = 1,663 | | 1–2 | 20.9% | 31.8%
Stewart, Lipton, and Simon, 1996 Follow-up to American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | | N = 1,663 | | 3–5 | 21.9% | 18.1%
Stewart, Lipton, and Simon, 1996 Follow-up to American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | | N = 1,663 | | 6–10 | 16.1% | 14.0%
Stewart, Lipton, and Simon, 1996 Follow-up to American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | | N = 1,663 | | 11–20 | 15.5% | 9.4%
Stewart, Lipton, and Simon, 1996 Follow-up to American Migraine Study | 11/88–12/88 Mail survey | IHS migraine | | N = 1,663 | | 21+ | 19.5% | 14.7%
van Roijen, Essink-Bot, Koopman schap, et al., 1995 | 10/92(interview) 6/93 (survey) Interview/survey | IHS migraine migraine + tension-type | Representative sample of the Dutch population age 12 years and older. Questioned 10,480 people in face-to-face interviews; of these, 992 met IHS criteria, had had a headache attack in the last 12 months, and agreed to oarticioate. | N =436 headache sufferers responded to the survey N = 585 non-headache controls | 10% of women and 2% of men reported some absence from work due to headache Based on a 2-week recall period, women reported 3.9 days/year and men 1.0 day/year absent from work due to headache Women had 22.8 hours/year and men 18.7 hours/year of reduced productivity due to headache Women reported having 73% efficiency at work with a headache and men 69% efficiency

Abbreviations: IHS = International Headache Society; Ltd. = Limited; mod = moderate; NHS = National Health Service; sev = severe; UK = United Kingdom; US = United States

1 Data collection on this study began prior to the release by the Ad Hoc Committee of its new definition of migraine. Study questions were not revised to reflect the new definition.