# Data Collection Form for Headache Cost Studies: Original Research

Source:

Dates of Data Collection:

Study Type:

Headache Definition Used:

Description of Study Population and Patient Sample Inclusion/Exclusion Criteria:

Intervention:

Method by Which Cost Results Were Obtained:

Results (include base year on which cost calculation is based):

Comments:

Reviewed by: __________

Date: __________

## Explanation of Terms Used in Data Collection Form for Cost Studies

Source. Give the first three authors of the study, full title, journal, date, volume, and page citation for each article.

Dates of data collection. List the inclusive dates during which patients were enrolled and follow-up data were collected.

Publication dates of reviewed studies. List the inclusive dates of studies included in review articles/meta-analyses, with special attention to the date of the most recent study.

Study type. Give study type, Meta analysis, review of literature, randomized controlled clinical trial, other controlled clinical trial, etc. At minimum indicate prospective or retrospective data collection and active intervention or observation of study patients.

Headache definition. State method by which headache was defined in study patients (e.g., International Classification, Ad Hoc Committee Classification) or if non-standard definition include the definition used by the authors.

Total study population. For original studies or meta-analyses, give the total number of patients observed and the total included in each subgroup in the analyses.

Patient inclusion/exclusion criteria. List the criteria by which patients were either included or excluded from the study.

Intervention. For original studies discuss the interventions applied to each group of patients in the study (Le., use of a new drug vs standard therapy or diagnostic test vs diagnostic test). What differences in the patterns of care of the patient groups are being tested?

Method of comparison. For review articles or meta analyses, describe the method by which comparisons are made between studies.

Method by which cost results were obtained. Describe the way in which costs (all direct and indirect) were calculated. Did the study actually calculate costs or did they really use charges? Indicate whether cost projections are based on a “gold-standard” of care or standard care currently provided. If actual costs were used, are the results discussed in terms of units of resources used or are costs used to project an estimated cost to some larger entity (e.g., a hospital, government program, or to the nation as a whole)? If cost projections are formulated, are numbers based on the incidence of headache or prevalence over a certain time period?

Results/conclusions. Describe as completely as possible the results of the study. State base year dollars in which results are given. Give descriptive information on patient population (sex, age, race, SES). Present results indicating all direct and indirect costs with direct costs classified as in-patient, out-patient, drug costs, or other expenses.

Comments. In this section please provide additional details which may facilitate future review of this data. Indicate if additional detailed results are available in the paper. Also include impression of overall study quality, especially if methodologic quality will call the results of the study into question.