# List of Excluded Articles

Articles passing the title-and-abstract screen but excluded from consideration in the report

| Reference | Disposition
1 | Adelman and Vonseggern, 1995 | Does not report original research (review article)
2 | Akpek, Arac, Atilla, et al., 1995 | Subject: Diagnostic imaging
3 | Appleby, 1996 | Does not report original research (review article)
4 | Baker, 1983 | Subject: Diagnostic imaging
5 | Beaty and Haynes, 1979 | No utilization or cost data reported
6 | Becker, Green, Beaufait, et al., 1993a | Subject: Diagnostic imaging
7 | Becker, Green, Beaufait, et al., 1993b | Subject: Diagnostic imaging
8 | Becker, Iverson, Reed, et al., 1988 | Subject: Diagnostic imaging
9 | Becker, Riess, and Hoag, 1996 | Methodological: Emergency room utilization data were reported on only the small fraction of treated patients who continued dihydroergotmaine (DHE) treatment for more than three months.
10 | Broadhead, Larson, Yarnall, et al., 1991 | No utilization or cost data reported
11 | Burke and Andrasik, 1989 | No utilization or cost data reported
12 | Business & Health, 1992 | Does not report original research (review article)
13 | Cady and Shealy, 1993 | No utilization or cost data reported
14 | Carrera, Gerson, Schnur, et al., 1977 | Subject: Diagnostic imaging
15 | Cull, Wells, and Miocevich, 1992 | COULD NOT OBTAIN COPY
16 | Cypress, 1981 | Does not report original research (review article)
17 | Dahlöf, 1995 | No utilization or cost data reported
18 | Davey and Leeder, 1992 | Does not report original research (review article)
19 | de Lissovoy and Lazarus, 1994 | Does not report original research (review article)
20 | Demaerel, Boelaert, Wilms, et al., 1996 | Subject: Diagnostic imaging
21 | Diamond and Medina, 1989 | Does not report original research (review article)
22 | Dumas, Pexman, and Kreeft, 1994 | Subject: Diagnostic imaging
23 | Feczko, 1992 | Does not report original research letter)
24 | Friedman and Taub, 1984 | No utilization or cost data reported
25 | Frolund and Frolund, 1986 | Population not primary headache
26 | Furlong, Pryse-Phillips, Crowley, et al., 1996 | Methodology: Utilization data were not a primary outcome of the study and were obtained haphazardly on small proportion of patients (less than 50%). Low follow-up rate severely biases the utilization results.
27 | Futterman and Hill, no date | Abstract only, no full report
28 | Ganiats, Carson, Hamm, et al., 1994 | Abstract only, no full report
29 | Ginsberg, Israeli, Cohen, et al., 1996 | Population not primary headache
30 | Greiner and Addy, 1996 | Methodology: Work loss data not quantifiable (only reported as increased, decreased or unchanged)
31 | Hackett, 1994 | Does not report original research (review article)
32 | Hoffert, 1994 | Does not report original research (review article)
33 | Holroyd and Penzien, 1990 | No utilization or cost data reported
34 | Hopkins, 1989 | Population/utilization data not specific for headache
35 | Hopkins, 1996 | No utilization or cost data reported
36 | Hudzinski and Zebrick, 1996 | Population not primary headache
37 | Ilacqua, 1994 | No utilization or cost data reported
38 | Jhingran, Cady, Rubino, et al., 1996 | No utilization or cost data reported
39 | Kahn, Sanders, Lyons, et al., 1993 | Subiect: Diagnostic imaging
40 | Kent, 1996 | Does not report original research (review article)
41 | Klapper, 1995 | No utilization or cost data reported
42 | Knaus and Davis, 1978 | Subject: Diagnostic imaging
43 | Knaus, Wagner, and Davis, 1981 | Subiect: Diagnostic imaging
44 | Kozma, Mauch, Reeder, et al., 1994 | Does not report original research (review article)
45 | Kozma and Reeder, 1995 | Does not report original research (review article)
46 | Kroenke and Mangelsdorff, 1989 | No utilization or cost data reported
47 | The Lancet, 1992 | Does not report original research (editorial)
48 | Larson, Omenn, and Lewis, 1980 | Subiect: Diagnostic imaging
49 | Lipton, Amatniek, Ferrari, et al., 1994 | Does not report original research (review article)
50 | Lipton, Stewart, and Von Korff, 1994 | Does not report original research (review article)
51 | Lipton, Stewart, and Von Korff, 1995 | Does not report original research (review article)
52 | Luciani, Osterhaus, and Gutterman, 1995 | No utilization or cost data reported
53 | Mayou, Seagroatt, and Goldacre, 1991 | Population/utilization data not specific for headache
54 | McGrath, Humphreys, Keene, et al., 1992 | No utilization or cost data reported
55 | Mitchell, Osborn, and Grosskreutz, 1993 | Subject: Diagnostic imaging
56 | Murray, 1963 | No utilization or cost data reported
57 | Nuechterlein and Holroyd, 1980 | No utilization or cost data reported
58 | Pascual, Polo, and Berciano, 1990 | No utilization or cost data reported
59 | Peters, Fraim, and Masel, 1983 | No utilization or cost data reported
60 | Rapoport, 1994 | Does not report original research (review article)
61 | Richardson and McGrath 1989 | Does not report original research (review article)
62 | Robinson, 1993 | Format: Data reported elsewhere
63 | Saadah, 1992 | No utilization or cost data reported
64 | Sage, Wilson, and Benness, 1980 | Subject: Diagnostic imaging
65 | Sands, Mulloy, Goldstein, et al., 1990 | Not primary headache population (population includes Diagnostic-Related Groups 24, 25, 26 [seizure with headache])
66 | Scarani, Beghi, and Tognoni, 1987 | Subject: Not related
67 | Silberstein and Lipton, 1996 | Does not report original research (review article)
68 | Silvestrini and Bernardi, 1994 | Subject: Diagnostic imaging
69 | Sinclair, Kovacs, Hillis, 1993 | Subject: Diagnostic imaging
70 | Solomon, 1994 | Does not report original research (review article)
71 | Spencer and Daugird, 1990 | No utilization or cost data reported
72 | Stang and Von Korff, 1994a | No utilization or cost data reported
73 | Stang and Von Korff, 1994b | No utilization or cost data reported
74 | Stang, Osterhaus, and Celentano, 1994 | Does not report original research (review article)
75 | Steiner, 1995 | Does not report original research (review article)
76 | Stewart and Lipton, 1994 | Does not report original research (review article)
77 | Stewart, Shechter, and Liberman, 1992 | Secondary analysis of previously published data
78 | Tansey, Pilgrim, and Lloyd, 1993 | No utilization or cost data reported
79 | Tfelt-Hansen, Henry, Mulder, et al., 1995 | No utilization or cost data reported
80 | To and Wu, 1995 | Methodological: Utilization data reported were for all causes; the proportion of physician consultation, emergency room use and hospitalization attributable to migraine were not described. Diagnosis of migraine was not collected systematically in the survey, but required that subjects volunteer this diagnosis.
81 | Turkewitz, Casaly, Dawson, et al., 1992 | No utilization or cost data reported
82 | Vernon, 1995 | Does not report original research (review article)
83 | Von Korff, Ormel, Keefe, et al., 1992 | No cost or utilization data reported
84 | Von Korff and Stang, 1994 | No utilization or cost data reported
85 | Von Korff, Stewart, and Lipton, 1994 | No utilization or cost data reported
86 | Von Korff, Wagner, Dworkin, et al., 1991 | Methodological: Utilization data not specific to migraine
87 | Von Seggern and Adelman, 1996 | Does not report original research (review article)
88 | Weingarten, Kleinman, Elperin, et al., 1992 | Subject: Diagnostic imaging
89 | Wilkinson, 1990 | Does not report original research (review article)
90 | Yabroff, Schulman, Kong, et al., | Abstract only, no full report
91 | Yen and McIntire, 1971 | Format: Case study
92 | Ziegler and Paolo, 1996 | No utilization or cost data reported