# Revised Electronic Search Strategy

1 | exp headache/
2 | headache$.tw.
3 | (head adj ache$).tw.
4 | 1 or 2 or 3
5 | cost$.tw.
6 | economi$.tw.
7 | practice pattern$.tw.
8 | exp “costs and cost analysis”/
9 | physician's practice patterns/
10 | exp drug utilization/
11 | ut.fs.
12 | 5 or 6 or 7 or 8 or 9 or 10 or 11
13 | 4 and 12

The search strategy was run in the Ovid version of the MEDLINE, HealthStar, and CINAHL databases.

Terms from the Medical Subject Heading (MeSH) lexicon/taxonomy are indicated in bold face; the term explode indicates that the immediately following MeSH heading and also those one or more levels beneath in the MeSH tree structure are included; for example exp drug utilization includes drug utilization review. The extension fs indicates that all citations coded with the antecedent MeSH subheading will be identified.

$ indicates unlimited truncation, used to retrieve all possible suffix variations of a root word (e.g., the search “disease$” would retrieve the word “disease,” as well as the words “diseases,” “diseased,” etc.

The adj operator requires that the query terms before and after will be found when adjacent and in the specified order.

The extension .tw indicates that the antecedent terms are used in a text-word search in titles and abstracts.