# Original Electronic Search Strategy

1 | exp headache/
2 | headache$.tw.
3 | (head adj ache$).tw.
4 | 1 or 2 or 3
5 | cost$.tw.
6 | economi$.tw.
7 | practice pattern$.tw.
8 | exp “costs and cost analysis”/
9 | physician's practice patterns/
10 | 5 or 6 or 7 or 8 or 9
11 | 4 and 10

The search strategy was run in Ovid version of the MEDLINE, HealthStar, and CINAHL databases.

$ indicates unlimited truncation, used to retrieve all possible suffix variations of a root word (e.g., the search “disease$” would retrieve the word “disease,” as well as the words “diseases,” “diseased,” etc.

The adj operator requires that the query terms before and after will be found when adjacent and in the specified order.

The extension .tw indicates that the antecedent terms is used in a text-word search in titles and abstracts.

The term exp indicates the explode function in which the indicated term and terms one or more levels beneath in the MeSH tree structure are included.