# Results

## Database of Nutrient-Outcome Associations

We identified a total of 34 eligible associations between nutrients and health outcomes (Table 1). Sixteen of 34 were based on meta-analyses of epidemiological studies and of RCTs that were reported in the same paper,12,19–27 11 were based on “matched” meta-analyses that were reported in separate papers,26,28–36 3 on a meta-analysis of observational studies matched with a large RCT (>1,000 participants),35,37–39 and 4 on a meta-analysis of RCTs matched with a large epidemiological study (>5,000 participants).40–45 Some of the included papers reported results from a meta-analyses of more than one nutrients and health outcome pair.

Table 1 Eligible nutrient-outcome associations

ID | Nutrient and Health Outcome | | | Epidemiological Studies | | | | RCTs
ID | Nutrient and Health Outcome | N Studies | N People | Summary OR (or WMD) | Recruitment/Publication Years | N Trials | N People | Summary OR (or WMD) | Recruitment (/Publication) years
1 | α-linolenic acid and systolic blood pressure (mmHg) | 1^45^ | 4,680 | WMD: −0.55 (−1.36, 0.26) | 1996–1999 | 3^44^ | 348 | WMD: −0.72 (−2.01,0.58) | 1990–2003
2 | α-linolenic acid and diastolic blood pressure (mmHg) | 1^45^ | 4,680 | WMD: −0.57(−1.13, −0.01) | 1996–1999 | 3^44^ | 348 | WMD: −0.17 (−0.82,0.48) | 1990–2003
3 | Beta-carotene and cervical cancer | 6^19^ | 1537 | 1.79 (0.72, 4.46) | 1991–2005 | 3^19^ | 553 | 0.95 (0.88,1.04) | 1991–2001
4 | Beta-carotene and acute macular degeneration | 4^19^ | 126,642 | 1.04 (0.86,1.25) | 1998–2005 | 2^19^ | 21,589 | 1.03 (0.89,1.19) | 1982–1992
5 | Beta-carotene and lung cancer | 10^23^ | 370,107 | 0.92 (0.83,1.01) | 1992–2003 | 6^23^ | 83,080 | 1.1 (0.89,1.36) | 1995–2003
6 | Beta-carotene and breast cancer incidence or mortality | 13^38^ | 210,962 | 0.82 (0.76, 0.91) | 1987–1996 | 1^39^ | 8171 | 1.01 (0.79, 1.3) | 1995–1996
7 | Beta-carotene (±Vitamin A) and esophageal cancer | 4^32^ | 2331 | 4^th^ vs. 1^st^ quartile: 0.46 (0.36,0.59) | 1996–2002 | 4^33^ | 33,055 | 1.16 (0.68,1.98) | 2003–2004
8 | Beta-carotene (± Vitamin A) and gastric cancer | 3^32^ | 29,908 | 4^th^ vs. 1^st^ quartile: 0.57 (0.46,0.72) | 2000–2005 | 5^33^ | 18,314 | 1.21 (0.6,2.44) | 1985–1998
9 | Beta-carotene and CHD/CVD events | 4^26^ | 18,256 | 1.26 (0.44,3.63) | 1999–2004 | 4^26^ | 84,687 | 1.26 (0.44,3.63) | 1996–2007
10 | Beta-carotene and CHD/CVD mortality | 4^26^ | 3,053 | 1.26 (0.44,3.63) | 1995–2004 | 4^34^ | 44,811 | 1.26 (0.44,3.63) | 1996–2007
11 | Calcium and hip fracture | 8^20^ | 239,597 | 1.00 (0.96, 1.04) | 1988–2003 | 4^20^ | 6740 | 0.92 (0.81,1.05) | 1994–2006
12 | Calcium (mother) and offspring systolic blood pressure (mmHg) | 2^21^ | 7283 | WMD: −0.71 (−2.92,1.51) | 1988–1995 | 2^21^ | 693 | WMD: −0.89 (−2.36, 0.59) | 1987–1998
13 | Calcium and diastolic blood pressure (mmHg) | 17^28^ | 38,950 | WMD: −0.01 (−0.019, −0.001) | 1983–1992 | 22^29^ | 2412 | WMD: −1.27 (−2.25, −0.29) | 1984–1994
14 | Calcium and systolic blood pressure (mmHg) | 17^28^ | 38,950 | WMD: −0.014 (−0.022, −0.005) | 1983–1992 | 22^29^ | 2412 | WMD: −0.24(−0.92, 0.44) | 1984–1994
15 | Fiber and colorectal adenoma/cancer | 1^41^ | 33,971 | 0.91 (0.86,0.97) | 1993–2000 | 5^40^ | 4349 | 1.04 (0.95,1.13) | 1983–2000
16 | Folate and cancer cervix | 8^19^ | 2835 | 0.89 (0.76,1.05) | 1988–2005 | 4^19^ | 687 | 0.99 (0.91,1.07) | 1982–1996
17 | Folate and CHD/CVD events | 4^26^ | 225,808 | 0.72 (0.59,0.87) | 1998–2006 | 4^26^ | 1701 | 0.94 (0.8,1.1) | 2004–2006
18 | Folic acid and stroke | 1^43^ | 43,732 | 5^th^ vs. 1^st^ quintile: 0.66 (0.45,0.98) | 1986–2000 | 8^42^ | 16,841 | 0.82 (0.68,1.0) | 1996–2006
19 | Omega-3 and all-cause mortality | 3^46^ | 3801 | 0.65 (0.48,0.88) | 1991–2003 | 15^46^ | 33,193 | 0.87 (0.73,1.03) | 1966–2003
20 | Omega-3 and cancer or cancer mortality | 7^46^ | 112,454 | 1.02 (0.87,1.19) | 1991–2001 | 10^46^ | 17,433 | 1.07 (0.88,1.3) | 1966–2003
21 | Omega-3 and combined CVD events | 7^46^ | 69,732 | 0.91 (0.73,1.13) | 1995–2003 | 18^46^ | 33,433 | 0.95 (0.82,1.12) | 1966–2003
22 | Omega-3 and stroke | 4^46^ | 52,026 | 1.17 (0.91,1.51) | 1995–2002 | 9^46^ | 31,073 | 1.17 (0.91,1.51) | 1966–2003
23 | Omega-3 and CHD mortality | 6^12^ | 83,578 | 0.62 (0.45, 0.86) | 1992–2007 | 10^12^ | 38,894 | 0.88 (0.82, 0.95) | 1995–2007
24 | Selenium and prostate cancer | 15^37^ | 168,226 | 0.72 (0.61,0.84) | 1988–2004 | 1^35^ | 1312 | 0.35 (0.18,0.65) | 1983–1991
25 | Vitamin C and breast cancer incidence or mortality | 13^38^ | 268,291 | 0.8 (0.68, 0.95) | 1991–1997 | 1^39^ | 8171 | 1.11 (0.87, 1.41) | 1995–1996
26 | Vitamin C and CHD/CVD events | 12^26^ | 12,419 | 0.82 (0.72, 0.92 | 1994–2004 | 1^26^ | 8,171 | 1.05 (0.93,1.19) | 1995–1996
27 | Vitamin C and CHD/CVD mortality | 12^26^ | 23,391 | 0.86 (0.6,1.24) | 1994–2003 | 1^34^ | 8,171 | 0.79 (0.4,1.55) | 1995–1996
28 | 25(OH)D and total cancer | 2^27^ | 30,149 | 6^th^ vs 1^st^ sextile: 1.49 (0.85,2.64) | 1988–2000 | 2^27^ | 3,865 | 0.76 (0.38,1.55) | 2003–2007
29 | Vitamin E and acute macular degeneration | 4^30^ | 124,307 | 0.83 (0.69,1.01) | 1998–2005 | 2^31^ | 1466 | 1.11(0.91,1.36) | 1982–2004
30 | Prenatal multivitamin and neural tube defects | 24^24^ | ND | 0.52 (0.39,0.69) | 1980–2004 | 4^24^ | ND | 0.67 (0.58,0.77) | 1988–2003
31 | Vitamin E and CHD/CVD events | 6^26^ | 184,594 | 0.77 (0.55, 0.99) | 1993–2009 | 11^26^ | 114,589 | 0.92 (0.84,1.01) | 1996–2008
32 | Vitamin E and CHD/CVD mortality | 9^26^ | 137,237 | 0.85 (0.78, 0.93 | 1996–2009 | 13^26^ | 111,481 | 0.97 (0.91,1.03) | 1996–2008
33 | Selenium and CHD | 22^22^ | 15,133 | 0.85 (0.74, 0.99) | 1982–2005 | 7^22^ | 17,766 | 0.43 (0.29, 0.66) | 1989–2004
34 | Selenium and lung cancer | 12^36^ | 1973 cases (total not reported) | 0.74 (0.57,0.97) | 1987–2002 | 1^35^ | 1312 | 0.54 (0.3,0.98) | 1983–1991

Abbreviations: CHD = chronic heart disease; CVD = cerebrovascular disease; ND = no data reported in the systematic reviews

In Table 1, 20 out of 34 associations pertained to vitamins, 7 pertained to minerals (such as calcium) and trace elements (such as selenium), and 7 to either macronutrients (fiber) or fatty acids. The examined endpoints span a wide range of clinical outcomes including mortality, stroke, and other cardiovascular outcomes, various cancers, acute macular degeneration, and fractures, and surrogate outcomes such as systolic and diastolic blood pressure. In two cases nutrient intake of the mother was examined with relation to a clinical outcome in the child (prenatal multivitamin supplementation in the mother and risk of neural tube defects in the fetus, and maternal calcium intake and blood pressure in the offspring).

## Concordance or Discordance Between Epidemiological and RCT Data

Table 2 shows concordance between the summary effects in the two research designs using the three definitions. Using the first definition, 6 out of 34 topics (18%) were qualitatively concordant, and the remaining 28 were classified as “unclear” (there was no topic with qualitatively discordant epidemiological and RCT data). Twelve of 34 associations (35%) had a statistically significant z-score, and using the second definition, evidence from epidemiological studies and evidence from RCTs was statistically significantly discordant. The remaining 22 associations had no evidence of significant discordance. Of the 12 association with a statistically significant z-score, in 6 the meta-analysis of the RCTs and that of the epidemiological studies pointed to different directions. Thus, six examples were quantitatively discordant using the third definition.

Table 2 Qualitative and quantitative concordance of effects in epidemiological studies and RCTs

ID | Direction of Effect (Epi) | Significance (Epi) | Direction of Effect (RCT) | Significance (RCT) | Qualitative Concordance (1st definition) | z-Score | p-Value | Quantitative Concordance (2nd definition) | Quantitative Concordance (3rd definition)
1 | Decreasing | Not sign | Decreasing | Not sign | Unclear | 0.22 | 0.83 | Not discordant | Not discordant
2 | Decreasing | Sign | Decreasing | Not sign | Unclear | −0.91 | 0.36 | Not discordant | Not discordant
3 | Increasing | Not sign | Decreasing | Not sign | Unclear | 1.36 | 0.18 | Not discordant | Not discordant
4 | Increasing | Not sign | Increasing | Not sign | Unclear | 0.08 | 0.94 | Not discordant | Not discordant
5 | Decreasing | Not sign | Increasing | Not sign | Unclear | −1.50 | 0.13 | Not discordant | Not discordant
6 | Decreasing | Sign | Increasing | Not sign | Unclear | −1.54 | 0.12 | Not discordant | Not discordant
7 | Decreasing | Sign | Increasing | Not sign | Unclear | −3.08 | 0.00 | Discordant | Discordant
8 | Decreasing | Sign | Increasing | Not sign | Unclear | −2.00 | 0.05 | Discordant | Discordant
9 | Increasing | Not sign | Increasing | Not sign | Unclear | 0.00 | 1.00 | Not discordant | Not discordant
10 | Increasing | Not sign | Increasing | Not sign | Unclear | 0.00 | 1.00 | Not discordant | Not discordant
11 | Increasing | Not sign | Decreasing | Not sign | Unclear | 1.20 | 0.23 | Not discordant | Not discordant
12 | Decreasing | Not sign | Decreasing | Not sign | Unclear | 0.13 | 0.89 | Not discordant | Not discordant
13 | Decreasing | Sign | Decreasing | Sign | Concordant | 2.52 | 0.01 | Discordant | Not discordant
14 | Decreasing | Sign | Decreasing | Not sign | Unclear | 0.65 | 0.51 | Not discordant | Not discordant
15 | Decreasing | Sign | Increasing | Not sign | Unclear | −2.48 | 0.01 | Discordant | Discordant
16 | Decreasing | Not sign | Decreasing | Not sign | Unclear | −1.15 | 0.25 | Not discordant | Not discordant
17 | Decreasing | Sign | Decreasing | Not sign | Unclear | −2.08 | 0.04 | Discordant | Not discordant
18 | Decreasing | Sign | Decreasing | Not sign | Unclear | −0.98 | 0.33 | Not discordant | Not discordant
19 | Decreasing | Sign | Decreasing | Not sign | Unclear | −1.64 | 0.10 | Not discordant | Not discordant
20 | Increasing | Not sign | Increasing | Not sign | Unclear | −0.37 | 0.71 | Not discordant | Not discordant
21 | Decreasing | Not sign | Decreasing | Not sign | Unclear | −0.31 | 0.75 | Not discordant | Not discordant
22 | Increasing | Not sign | Increasing | Not sign | Unclear | 0.00 | 1.00 | Not discordant | Not discordant
23 | Decreasing | Sign | Decreasing | Sign | Concordant | −2.07 | 0.04 | Discordant | Not discordant
24 | Decreasing | Sign | Decreasing | Sign | Concordant | 2.14 | 0.03 | Discordant | Not discordant
25 | Decreasing | Sign | Increasing | Not sign | Unclear | −2.19 | 0.03 | Discordant | Discordant
26 | Decreasing | Sign | Increasing | Not sign | Unclear | −2.79 | 0.01 | Discordant | Discordant
27 | Decreasing | Not sign | Decreasing | Not sign | Unclear | 0.22 | 0.83 | Not discordant | Not discordant
28 | Increasing | Not sign | Decreasing | Not sign | Unclear | 1.46 | 0.14 | Not discordant | Not discordant
29 | Decreasing | Not sign | Increasing | Not sign | Unclear | −2.06 | 0.04 | Discordant | Discordant
30 | Decreasing | Sign | Decreasing | Sign | Concordant | −1.56 | 0.12 | Not discordant | Not discordant
31 | Decreasing | Sign | Decreasing | Not sign | Unclear | −1.13 | 0.26 | Not discordant | Not discordant
32 | Decreasing | Sign | Decreasing | Not sign | Unclear | −2.41 | 0.02 | Discordant | Not discordant
33 | Decreasing | Sign | Decreasing | Sign | Concordant | 3.06 | 0.00 | Discordant | Not discordant
34 | Decreasing | Sign | Decreasing | Sign | Concordant | 0.95 | 0.34 | Not discordant | Not discordant

Note: Sign = statistically significant at the 0.05 level

### Citation Graphs

We were able to construct citation graphs for 28 topics (Table 3). For 6 topics we were unable to form reliable citation graphs (for technical reasons related to changes in the format of the citation information obtained from the ISI Web site). Briefly, there was variability in the total number of vertices in the 28 citation graphs: The median number of vertices (articles) was 253 (25^th^–75^th^ percentiles: 95, 356), and the median number of edges (citation relationships) was 1181 (25^th^–75^th^ percentiles: 255, 1620). The citation graphs are relatively sparsely connected with median density 0.018 (low density or low connectivity is the norm for citation graphs). The table shows also the mean hub and authority scores across all papers in a graph, and across the 20 papers with the highest respective scores. Graphs with higher mean hub scores and higher mean authority scores have more papers that “integrate” and “provide” information (as conveyed by citaiton relationships), respectively, compared with graphs with lower scores. When all papers in a graph were considered, the median hub score was 0.09 (25^th^–75^th^ percentiles: 0.07, 0.13) and the median authority score was 0.13 (25^th^–75^th^ percentiles: 0.10, 0.21). Finally, similar variability across the 28 topics was observed in the mean number of citation received, citations made, or total citations made or received. When all papers in a graph were considered the median numbers and 25^th^–75^th^ percentile ranges were 4.3 (3.2, 4.7), 4.3 (3.2, 4.7) and 8.5 (6.3, 9.4), respectively. (When all papers are considered in a citation graph, the mean number of citations made equals the mean number of citations received.) The corresponding mean scores or numbers over the 20 papers with the largest respective scores or numbers are also shown (Table 3).

Table 3 Summary of citation analysis of nutrient exposure-health outcome pairs studied by systematic reviews or large studies

ID | Vertices | Citation Relationships | Citation Density (*10^−3) | Mean Hub Score | | Mean Authority Score | | Mean Citations Made | | Mean Citations Received | | Mean Citations Made or Received
ID | Vertices | Citation Relationships | Citation Density (*10^−3)
ID | Vertices | Citation Relationships | Citation Density (*10^−3) | All | Top 20 | All | Top 20 | All^*^ | Top 20 | All^*^ | Top 20 | All | Top 20
1 | 91 | 226 | 27.6 | 0.11 | 0.35 | 0.10 | 0.31 | 2.48 | 7.00 | 2.48 | 5.95 | 4.97 | 11.00
2 | 91 | 226 | 27.6 | 0.11 | 0.35 | 0.10 | 0.31 | 2.48 | 7.00 | 2.48 | 5.95 | 4.97 | 11.00
3 | 62 | 264 | 69.8 | 0.22 | 0.53 | 0.21 | 0.48 | 4.26 | 9.05 | 4.26 | 9.70 | 8.52 | 14.55
4 | 60 | 220 | 62.1 | 0.19 | 0.45 | 0.23 | 0.53 | 3.67 | 8.20 | 3.67 | 8.25 | 7.33 | 13.40
5 | 254 | 1131 | 17.6 | 0.07 | 0.40 | 0.13 | 0.52 | 4.45 | 18.25 | 4.45 | 22.45 | 8.91 | 31.15
6 | 463 | 1784 | 8.3 | 0.13 | 0.80 | 0.04 | 0.32 | 3.85 | 29.00 | 3.85 | 21.50 | 7.71 | 37.70
7 | 365 | 1721 | 13.0 | 0.07 | 0.50 | 0.09 | 0.51 | 4.72 | 25.00 | 4.72 | 27.45 | 9.43 | 38.65
8 | 365 | 1721 | 13.0 | 0.07 | 0.50 | 0.09 | 0.51 | 4.72 | 25.00 | 4.72 | 27.45 | 9.43 | 38.65
9 | – | – | – | – | – | – | – | – | – | – | – | – | –
10 | – | – | – | – | – | – | – | – | – | – | – | – | –
11 | 173 | 556 | 18.7 | 0.10 | 0.48 | 0.09 | 0.50 | 3.21 | 13.95 | 3.21 | 13.15 | 6.43 | 21.00
12 | 183 | 565 | 17.0 | 0.25 | 0.74 | 0.04 | 0.22 | 3.09 | 17.35 | 3.09 | 10.55 | 6.17 | 20.95
13 | 279 | 1447 | 18.7 | 0.09 | 0.59 | 0.11 | 0.54 | 5.19 | 26.55 | 5.19 | 35.15 | 10.37 | 44.15
14 | 279 | 1447 | 18.7 | 0.09 | 0.59 | 0.11 | 0.54 | 5.19 | 26.55 | 5.19 | 35.15 | 10.37 | 44.15
15 | 60 | 189 | 53.4 | 0.17 | 0.41 | 0.27 | 0.64 | 3.15 | 6.45 | 3.15 | 6.95 | 6.30 | 11.05
16 | 39 | 200 | 135.0 | 0.28 | 0.50 | 0.30 | 0.50 | 5.13 | 8.55 | 5.13 | 8.70 | 10.26 | 14.50
17 | 252 | 1911 | 30.2 | 0.08 | 0.44 | 0.24 | 0.78 | 7.58 | 27.70 | 7.58 | 42.45 | 15.17 | 51.70
18 | 360 | 2602 | 20.1 | 0.05 | 0.40 | 0.21 | 0.78 | 7.23 | 29.15 | 7.23 | 51.00 | 14.46 | 60.65
19 | 406 | 1230 | 7.5 | 0.02 | 0.25 | 0.11 | 0.75 | 3.03 | 14.50 | 3.03 | 19.05 | 6.06 | 25.40
20 | – | – | – | – | – | – | – | – | – | – | – | – | –
21 | – | – | – | – | – | – | – | – | – | – | – | – | –
22 | – | – | – | – | – | – | – | – | – | – | – | – | –
23 | 392 | 2741 | 17.9 | 0.06 | 0.50 | 0.12 | 0.67 | 5.59 | 30.70 | 5.59 | 39.35 | 11.19 | 51.45
24 | 159 | 779 | 31.0 | 0.08 | 0.36 | 0.16 | 0.58 | 4.90 | 16.60 | 4.90 | 20.05 | 9.80 | 29.30
25 | 463 | 1784 | 8.3 | 0.13 | 0.80 | 0.04 | 0.32 | 3.85 | 29.00 | 3.85 | 21.50 | 7.71 | 37.70
26 | 98 | 255 | 26.8 | 0.09 | 0.30 | 0.18 | 0.64 | 2.60 | 8.55 | 2.60 | 7.35 | 5.20 | 12.10
27 | 98 | 255 | 26.8 | 0.09 | 0.30 | 0.18 | 0.64 | 2.60 | 8.55 | 2.60 | 7.35 | 5.20 | 12.10
28 | – | – | – | – | – | – | – | – | – | – | – | – | –
29 | 60 | 220 | 62.1 | 0.19 | 0.45 | 0.23 | 0.53 | 3.67 | 8.20 | 3.67 | 8.25 | 7.33 | 13.40
30 | 280 | 1294 | 16.6 | 0.08 | 0.57 | 0.12 | 0.49 | 4.62 | 18.35 | 4.62 | 28.75 | 9.24 | 34.10
31 | 351 | 1519 | 12.4 | 0.04 | 0.35 | 0.14 | 0.68 | 4.33 | 23.20 | 4.33 | 34.40 | 8.66 | 44.65
32 | 351 | 1519 | 12.4 | 0.04 | 0.35 | 0.14 | 0.68 | 4.33 | 23.20 | 4.33 | 34.40 | 8.66 | 44.65
33 | 116 | 397 | 29.8 | 0.07 | 0.30 | 0.21 | 0.70 | 3.42 | 11.00 | 3.42 | 12.85 | 6.84 | 19.00
34 | 302 | 1292 | 14.2 | 0.05 | 0.38 | 0.10 | 0.62 | 4.28 | 21.15 | 4.28 | 23.85 | 8.56 | 33.10

Some association topics share the same citation graph (those with identical numbers – see text).

* In each topic, when all papers are considered, the mean citations made and received are the same. The corresponding numbers differ when only the subset of 20 papers with the highest number of citations made or received are considered.

## Associations Between Citation Graph Metrics and Qualitative and Quantitative Concordance

There was no association between the characteristics of the citation graphs and the observed qualitative or quantitative concordance in the 28 analyzable topics (Table 4). The table shows analyses in which the predictors (numbers or mean scores) were log transformed using the base 2. Thus, the odds ratios in the table represent the change in the odds of finding concordance per doubling of the value of the predictor. The p-values remain identical for any other logarithmic transformation of the predictors. Analyses using other transformations (square root, no transformation) were qualitatively similar. It appears that the examined connectivity metrics of the citations maps do not correlate with the likelihood that the summary findings from meta-analyses of epidemiological studies and of RCTs are in qualitative or quantitative agreement.

Table 4 Associations between concordance and quantitative characteristics of the citation graphs

Citation Graph Metric | Qualitative | Concordance | Quantitative | Concordance | Quantitative | Concordance
Citation Graph Metric | (First | Definition) | (Second | Definition) | (Third | Definition)
Citation Graph Metric | OR (95% CI)^*^ | P-value | OR (95% CI)^*^ | P-value | OR (95% CI)^*^ | P-value
Among all papers
Papers (vertices) | 1.57 (0.60, 4.10) | 0.33 | 0.82 (0.40, 1.68) | 0.59 | 1.15 (0.38, 2.00) | 0.74
Citation relationships (edges) | 1.65 (0.74, 3.70) | 0.19 | 0.78 (0.44, 1.40) | 0.40 | 1.21 (0.42, 1.64) | 0.59
Graph citation density | 0.83 (0.32, 2.18) | 0.70 | 1.03 (0.48, 2.21) | 0.95 | 1.01 (0.39, 2.51) | 0.99
Hub score (mean) | 0.54 (0.16, 1.86) | 0.32 | 1.19 (0.46, 3.02) | 0.72 | 0.62 (0.51, 5.12) | 0.41
Authority score (mean) | 1.15 (0.34, 3.91) | 0.82 | 0.70 (0.26, 1.88) | 0.47 | 1.14 (0.30, 2.60) | 0.81
Citations made (mean) | 3.11 (0.28, 34.59) | 0.35 | 0.44 (0.07, 3.00) | 0.40 | 2.25 (0.04, 4.41) | 0.48
Citations received (mean) | 3.11 (0.28, 34.59) | 0.35 | 0.44 (0.07, 3.00) | 0.40 | 2.25 (0.04, 4.41) | 0.48
Total citations (mean) | 3.11 (0.28, 34.59) | 0.35 | 0.44 (0.07, 3.00) | 0.40 | 2.25 (0.04, 4.41) | 0.48
Among the 20 papers with the highest number or score
Hub score (mean) | 0.74 (0.08, 7.35) | 0.80 | 1.13 (0.19, 6.74) | 0.89 | 0.52 (0.24, 15.83) | 0.54
Authority score (mean) | 3.70 (0.22, 62.12) | 0.32 | 0.26 (0.03, 2.04) | 0.16 | 1.11 (0.12, 6.70) | 0.92
Citations made (mean) | 1.73 (0.43, 6.98) | 0.42 | 0.70 (0.25, 1.98) | 0.50 | 1.26 (0.24, 2.63) | 0.71
Citations received (mean) | 1.97 (0.62, 6.27) | 0.22 | 0.74 (0.32, 1.68) | 0.46 | 1.47 (0.26, 1.80) | 0.43
Total citations (mean) | 1.94 (0.50, 7.53) | 0.31 | 0.70 (0.26, 1.89) | 0.48 | 1.50 (0.21, 2.12) | 0.49

* per doubling of the predictor (score or number).