# References

1 Esmaillzadeh A, Kimiagar M, Mehrabi Y, et al. Fruit and vegetable intakes, C-reactive protein, and the metabolic syndrome. Am J Clin Nutr. Dec. 2006;84(6):1489-97. [pmid: 17158434].
2 Koushik A, Hunter DJ, Spiegelman D, et al. Intake of the major carotenoids and the risk of epithelial ovarian cancer in a pooled analysis of 10 cohort studies. Int J Cancer. Nov. 1. 2006;119(9):2148-54. [pmid: 16823847].
3 Lee JE, Giovannucci E, Smith-Warner SA, et al. Intakes of fruits, vegetables, vitamins A, C, and E, and carotenoids and risk of renal cell cancer. Cancer Epidemiol Biomarkers Prev. Dec. 2006;15(12):2445-52. [pmid: 17164369].
4 Lin J, Zhang SM, Cook NR, et al. Dietary intakes of fruit, vegetables, and fiber, and risk of colorectal cancer in a prospective cohort of women (United States). Cancer Causes Control. Apr. 2005;16(3):225-33. [pmid: 15947874].
5 Shai I, Jiang R, Manson JE, et al. Ethnicity, obesity, and risk of type 2 diabetes in women: a 20-year follow-up study. Diabetes Care. Jul. 2006;29(7):1585-90. [pmid: 16801583].
6 Schatzkin A, Lanza E, Corle D, et al. Lack of effect of a low-fat, high-fiber diet on the recurrence of colorectal adenomas. Polyp Prevention Trial Study Group. N Engl J Med. Apr. 20. 2000;342(16):1149-55. [pmid: 10770979].
7 Yusuf S, Dagenais G, Pogue J, et al. Vitamin E supplementation and cardiovascular events in high-risk patients. The Heart Outcomes Prevention Evaluation Study Investigators. N Engl J Med. Jan. 20. 2000;342(3):154-60. [pmid: 10639540].
8 The effect of vitamin E and beta carotene on the incidence of lung cancer and other cancers in male smokers. The Alpha-Tocopherol, Beta Carotene Cancer Prevention Study Group. N Engl J Med. Apr. 14. 1994;330(15):1029-35. [pmid: 8127329].
9 Rapola JM, Virtamo J, Ripatti S, et al. Randomised trial of alpha-tocopherol and beta-carotene supplements on incidence of major coronary events in men with previous myocardial infarction. Lancet. Jun. 14. 1997;349(9067):1715-20. [pmid: 9193380].
10 Sesso HD, Buring JE, Christen WG, et al. Vitamins E and C in the prevention of cardiovascular disease in men: the Physicians’ Health Study II randomized controlled trial. JAMA. Nov. 12. 2008;300(18):2123-33. [pmid: 18997197].
11 Bazzano LA, Reynolds K, Holder KN, et al. Effect of folic acid supplementation on risk of cardiovascular diseases: a meta-analysis of randomized controlled trials. JAMA. Dec. 13. 2006;296(22):2720-6. [pmid: 17164458].
12 Trikalinos TA, Moorthy D, Chung M, et al. Concordance of randomized and nonrandomized studies was unrelated to translational patterns of two nutrient-disease associations. J Clin Epidemiol. Jan. 2012;65(1):16-29. [pmid: 22047889].
13 World Cancer Research Fund, American Institute for Cancer Research. World Cancer Research Fund International’s Report on Diet, Nutrition, Physical Activity and Cancer. London. WCRF/AICR. 2007. www.dietandcancerreport.org/expert_report/view_slrs.php. Accessed January 14, 2010.
14 Batagelj V. Efficient algorithms for citation network analysis. 2003. http://arxiv.org/pdf/cs/0309023.pdf. Accessed January 14, 2010.
15 deNooy W, Mrvar A, Batagelj V. Exploratory social network analysis with Pajek. Granovetter M, editor. Structural analysis in the social sciences. New York. Cambridge University Press. 2005.
16 Clark J, Holton DA. A first look at graph theory. World Scientific. 1991.
17 Koller D, Friedman N. Probabilistic graphical models - principles and techniques. Cambridge. The MIT Press. 2009.
18 Rimm EB, Stampfer MJ, Ascherio A, et al. Vitamin E consumption and the risk of coronary heart disease in men. N Engl J Med. May. 20. 1993;328(20):1450-6. [pmid: 8479464].
19 Agnoli C, Berrino F, Canevari S, et al. World Cancer Research Fund International’s Report on Diet, Nutrition, Physical Activity and Cancer, The Associations between Food, Nutrition and Physical Activity and the Risk of Cervical Cancer and Underlying Mechanisms. London. WCRF/AICR. 2007. www.dietandcancerreport.org/expert_report/view_slrs.php. Accessed January 14, 2010.
20 Bischoff-Ferrari HA, Dawson-Hughes B, Baron JA, et al. Calcium intake and hip fracture risk in men and women: a meta-analysis of prospective cohort studies and randomized controlled trials. Am J Clin Nutr. Dec. 2007;86(6):1780-90. [pmid: 18065599].
21 Brion MJ, Leary SD, Lawlor DA, et al. Modifiable maternal exposures and offspring blood pressure: a review of epidemiological studies of maternal age, diet, and smoking. Pediatr Res. Jun. 2008;63(6):593-8. [pmid: 18317238].
22 Flores-Mateo G, Navas-Acien A, Pastor-Barriuso R, et al. Selenium and coronary heart disease: a meta-analysis. Am J Clin Nutr. Oct. 2006;84(4):762-73. [pmid: 17023702].
23 Gallicchio L, Boyd K, Matanoski G, et al. Carotenoids and the risk of developing lung cancer: a systematic review. Am J Clin Nutr. Aug. 2008;88(2):372-83. [pmid: 18689373].
24 Goh YI, Bollano E, Einarson TR, et al. Prenatal multivitamin supplementation and rates of congenital anomalies: a meta-analysis. J Obstet Gynaecol Can. Aug. 2006;28(8):680-9. [pmid: 17022907].
25 Hooper L, Thompson RL, Harrison RA, et al. Risks and benefits of omega 3 fats for mortality, cardiovascular disease, and cancer: systematic review. BMJ. Apr. 1. 2006;332(7544):752-60. [pmid: 16565093].
26 Mente A, de KL, Shannon HS, et al. A systematic review of the evidence supporting a causal link between dietary factors and coronary heart disease. Arch Intern Med. Apr. 13. 2009;169(7):659-69. [pmid: 19364995].
27 Chung M, Balk M, Brendel M, et al. Vitamin D and Calcium: A Systematic Review of Health Outcomes. Evidence Reports/Technology Assessments, No. 183. Rockville, MD. Agency for Healthcare Research and Quality. 2009. https://www.ncbi.nlm.nih.gov/books/NBK32603. Accessed January 10, 2012.
28 Cappuccio FP, Elliott P, Allender PS, et al. Epidemiologic association between dietary calcium intake and blood pressure: a meta-analysis of published data. Am J Epidemiol. Nov. 1. 1995;142(9):935-45. [pmid: 7572974].
29 Bucher HC, Cook RJ, Guyatt GH, et al. Effects of dietary calcium supplementation on blood pressure. A meta-analysis of randomized controlled trials. JAMA. Apr. 3. 1996;275(13):1016-22. [pmid: 8596234].
30 Chong EW, Wong TY, Kreis AJ, et al. Dietary antioxidants and primary prevention of age related macular degeneration: systematic review and meta-analysis. BMJ. Oct. 13. 2007;335(7623):755. [pmid: 17923720].
31 Evans J. Antioxidant supplements to prevent or slow down the progression of AMD: a systematic review and meta-analysis. Eye (Lond). Jun. 2008;22(6):751-60. [pmid: 18425071].
32 Kubo A, Corley DA. Meta-analysis of antioxidant intake and the risk of esophageal and gastric cardia adenocarcinoma. Am J Gastroenterol. Oct. 2007;102(10):2323-30. [pmid: 17581269].
33 Bjelakovic G, Nikolova D, Simonetti RG, et al. Antioxidant supplements for prevention of gastrointestinal cancers: a systematic review and meta-analysis. Lancet. Oct. 2. 2004;364(9441):1219-28. [pmid: 15464182].
34 Ye Z, Song H. Antioxidant vitamins intake and the risk of coronary heart disease: meta-analysis of cohort studies. Eur J Cardiovasc Prev Rehabil. Feb. 2008;15(1):26-34. [pmid: 18277182].
35 Clark LC, Combs GF Jr, Turnbull BW, et al. Effects of selenium supplementation for cancer prevention in patients with carcinoma of the skin. A randomized controlled trial. Nutritional Prevention of Cancer Study Group. JAMA. Dec. 25. 1996;276(24):1957-63. [pmid: 8971064].
36 Zhuo H, Smith AH, Steinmaus C. Selenium and lung cancer: a quantitative analysis of heterogeneity in the current epidemiological literature. Cancer Epidemiol Biomarkers Prev. May. 2004;13(5):771-8. [pmid: 15159309].
37 Etminan M, FitzGerald JM, Gleave M, et al. Intake of selenium in the prevention of prostate cancer: a systematic review and meta-analysis. Cancer Causes Control. Nov. 2005;16(9):1125-31. [pmid: 16184479].
38 Gandini S, Merzenich H, Robertson C, et al. Meta-analysis of studies on breast cancer risk and diet: the role of fruit and vegetable consumption and the intake of associated micronutrients. Eur J Cancer. Mar. 2000;36(5):636-46. [pmid: 10738129].
39 Lin J, Cook NR, Albert C, et al. Vitamins C and E and beta carotene supplementation and cancer risk: a randomized controlled trial. J Natl Cancer Inst. Jan. 7. 2009;101(1):14-23. [pmid: 19116389].
40 Asano TK, McLeod RS. Dietary fibre for the prevention of colorectal adenomas and carcinomas. Cochrane Database of Systematic Reviews. 2002. 1. Art. No: CD003430. [doi: 10.1002/14651858.CD003430].
41 Peters U, Sinha R, Chatterjee N, et al. Dietary fibre and colorectal adenoma in a colorectal cancer early detection programme. Lancet. May. 3. 2003;361(9368):1491-95. [pmid: 12737857].
42 Wang X, Qin X, Demirtas H, et al. Efficacy of folic acid supplementation in stroke prevention: a meta-analysis. Lancet. Jun. 2. 2007;369(9576):1876-82. [pmid: 17544768].
43 He K, Merchant A, Rimm EB, et al. Folate, vitamin B6, and B12 intakes in relation to risk of stroke among men. Stroke. Jan. 2004;35(1):169-74. [pmid: 14671243].
44 Wendland E, Farmer A, Glasziou P, et al. Effect of alpha linolenic acid on cardiovascular risk markers: a systematic review. Heart. Feb. 2006;92(2):166-9. [pmid: 15890766].
45 Ueshima H, Stamler J, Elliott P, et al. Food omega-3 fatty acid intake of individuals (total, linolenic acid, long-chain) and their blood pressure: INTERMAP study. Hypertension. Aug. 2007;50(2):313-19. [pmid: 17548718].
46 Hooper L, Thompson RL, Harrison RA, et al. Omega 3 fatty acids for prevention and treatment of cardiovascular disease. Cochrane Database Syst Rev. 2004;(4):CD003177. [pmid: 15495044].
47 Hummon N, Doreian P. Connectivity in a citation network: the development of DNA theory. Social Networks. 1989;11:39-63.
48 Greenberg SA. How citation distortions create unfounded authority: analysis of a citation network. BMJ. 2009;339:b2680. [pmid: 19622839].