# Methods

## Overview

We developed a database of nutrient associations of health outcomes that have been examined in published meta-analyses of epidemiological studies and of RCTs. We term the studies included in the meta-analyses “index studies” or “index RCTs,” respectively. For each pair of meta-analyses (each nutrient-outcome association) we defined an “evidence base” including all publications identifiable by MEDLINE^®^ searches on the nutrient and outcome of interest. This evidence base included all index studies or RCTs. We recorded the citations made by the index studies and the index RCTs among the publications in the evidence base, and created the respective citation graphs, that is, “maps” that encode which papers in the evidence base are cited by index studies or index RCTs, either directly, or through one or more intermediary papers. We then calculated quantitative metrics that describe the connectivity of the citation graphs, and tested for associations between these metrics and the probability that the summary results from epidemiological studies and from RCTs are concordant between them.

## Database of Associations Between Nutrients and Health Outcomes

We identified associations between nutrients and health outcomes that were examined in epidemiological studies and in RCTs. More specifically, we defined a nutrient as any non–energy-yielding nutrient (e.g., vitamins and minerals) or any nutrient that provides some energy but does not contribute as major source of energy intakes in a regular diet (i.e., carbohydrate, protein, and fat). An example of the latter is n-3 polyunsaturated fatty acids (hereon called “omega-3”). We accepted clinical outcomes such as mortality or cardiovascular disease, and surrogate endpoints, such as difference in blood pressure. To be eligible for inclusion in the database, the same nutrient-outcome association should be examined in epidemiological studies and in RCTs.

There is a plethora of publications on the relationship between nutrients and health outcomes. For feasibility, we prioritized associations that have been “well studied” with epidemiological studies and with RCTs. We operationally defined as well-studied associations those for which we could find at least one published meta-analysis of epidemiologic data and at least one meta-analysis of RCTs. If there was only a meta-analysis of observational data but no meta-analysis of RCTs on the same association, we accepted a large RCT (>1000 participants) instead of a meta-analysis, if any existed. Correspondingly, we accepted a single epidemiological study (>5000 participants) instead of a meta-analysis of epidemiological data, if we could identify a meta-analysis of RCTs but no meta-analysis of epidemiological data on the same association.

### Literature Searches To Identify Meta-Analyses on Nutrients

We searched MEDLINE from 1996 to March 2009 to identify all systematic reviews with meta-analyses that examined our prespecified list of nutrients. We supplemented MEDLINE searches by perusing the list of systematic reviews included in the World Cancer Research Fund International’s Report on Diet, Nutrition, Physical Activity and Cancer.13

### Matching Meta-Analyses of Epidemiological Studies With Meta-Analyses of RCTs

We matched meta-analyses of epidemiological studies and of RCTs (or meta-analyses and large studies) using the following algorithm:

1. First, we identified all systematic review publications that included both a meta-analysis of observational studies and a meta-analysis of RCTs. We assumed that meta-analyses of epidemiological studies and of RCTs reported in the same paper were “matched,” i.e., referred to the same nutrient-outcome association, provided that there was not clear statement suggesting otherwise.
2. Subsequently, we identified papers reporting only meta-analyses of epidemiological studies or meta-analyses of RCTs. We “matched” a meta-analysis of epidemiological studies with a meta-analysis of RCTs if both examined the same nutrient in relation to the same health outcome, and irrespective of differences in the inclusion or exclusion criteria for populations, the meta-analyses’ publication dates, or the time periods covered by their searches. If a publication contained more than one meta-analysis on different nutrient-outcome combinations, we considered each nutrient-outcome combination separately.
3. Finally, for all remaining meta-analyses of epidemiological studies that were not matched with a meta-analysis of RCTs, we tried to identify a large RCT (of more than 1000 participants) on the same association as a match. Analogously, we tried to identify large epidemiological studies (>5000 participants) to pair with each remaining meta-analyses of RCTs. To find a matching “large” observational study, we compiled a list of all large cohorts included in matched meta-analyses of steps (i) and (ii), as well as additional well-known cohorts (list provided in Appendix A), and examined whether they had publications on the same nutrient-outcome association as an yet unmatched meta-analysis of RCTs by perusing the cohort’s Web site (if one exists), or by a focused MEDLINE search.

### Data Extraction

We extracted the following details from our database of matched pairs: number of studies in each meta-analysis, summary effect sizes, number of studies for different study designs, and years of recruitment for the studies (year of publication was used instead, if recruitment details were not reported in the meta-analysis).

### Assessment of Concordance or Discordance Between Epidemiological Studies and RCTs

We calculated agreement between the reported meta-analysis findings of observational data and of RCTs using three definitions. We defined “qualitative” concordance based on the direction of the summary effect sizes and their statistical significance. We defined as qualitatively concordant summary effects in epidemiological studies and in RCTs that were statistically significant (at the 0.05 level) and in the same direction (e.g., both summary odds ratios suggesting lower risk of disease), as qualitatively discordant statistically significant summary effects in opposite directions, and all other cases as “unclear”.

Alternatively, we defined quantitative discordance by testing whether the difference in the summary effects of epidemiological studies and of RCTs was statistically significant or not, based on a z-score: z = (e f f e c t_e p i d e m i o l o g i c a l_ - e f f e c t_R C T_)/(sqrt(v a r i a n c e_e p i d e m i o l o g i c a l_ + v a r i a n c e_R C T_)) ~ N ( 0 , 1 ) . Associations with a p-value below 0.05, were considered discordant, while those with a p-value of at least 0.05 were not discordant. Finally, we also used a third, stricter definition of discordance, where we considered as discordant associations where the z-score was significant and summary findings of RCTs and observational studies pointed in different directions. For example, an association in which the meta-analysis of RCTs and epidemiological studies point in the same direction but have sufficiently different magnitudes so that the aforementioned z-score is statistically significant would be considered qualitatively concordant (as per the first definition), quantitatively discordant (as per the second definition), and quantitatively not discordant (with the third definition).

As described in a later paragraph, we assessed relationships between quantitative characteristics of the citation graphs in each association and the concordance between evidence from epidemiological studies and from RCTs.

## Citation Analyses

### Identifying an Evidence Base for Each Association

For each association we searched MEDLINE to identify an evidence base of publications relevant to the nutrients and disease of interest, using proper keywords and MeSH terms. We limited searches to English-language publications and to the years searched by the original systematic reviews. When these were not reported, we searched from inception of MEDLINE to the year of publication of the systematic review. We did not use search filters for specific research designs nor limited searches to humans.

For feasibility, we revised the search strategies (by adding or removing terms for nutrients or outcomes) to return approximately 3,000 and no more than 5,000 papers. Although arbitrary, these numbers are typical for systematic reviews. We refined the searches until they missed at most three index publications. If the search missed one to three index publications, these were added manually to the evidence base.

### Citation Networks and Graphs

For each association we constructed the citation networks of the RCTs and observational studies included in our systematic reviews (“index” articles) and represented them as citation graphs. Appendix B provides details on how we formed the citation graphs and how we checked that they possess and fulfill theoretically anticipated properties and constraints. Briefly, among the articles in the evidence base of each association, we identified all articles cited by the index studies directly or after following citation links through one or more intermediary papers.

A citation graph describes citation relationships between articles in the evidence base (see example in Figure 1). Articles are represented by vertices and citation relationships by arcs that connect pairs of vertices. The direction of each arc is from the cited towards the citing article (following the flow of information). Representing citation relationships as graphs allows us to use tools from graph theory and network analysis 14–17 to characterize the evidence base and the apparent information flow in it. Without loss of clarity, we use the terms “citation network” and “citation graph” interchangeably. We then proceeded to analyze these citation networks in each association as discussed below.

Figure 1 Illustration of a hypothetical citation network of six articles

The figure shows a citation network (represented as a citation graph) in a hypothetical evidence base of 6 articles. Each article is depicted by a vertex (A through F). The horizontal placement of the articles corresponds to their year of publication, their vertical arrangement is arbitrary – its main purpose is clarity of presentation. Arcs denote citation relationships. The direction of the arc indicates flow of information from the cited paper (beginning of the arc) to the citing paper (end of the arc). In the figure 5 out of 6 papers (papers B through F) are connected with citation arcs. There are 4 observed citation arcs (B→D, C→D, C→E, and D→F) out of a total of 14 possible ones (from any earlier- to any subsequently-published article). The density of the citation relationships is defined as the ratio of observed to possible citation arcs, i.e., here it is 4/14=0.29. Citation graphs have characteristics and properties that are described in the Appendix. Briefly, citation arcs are simple directed acyclic graphs: (1) An article does not cite itself, and there is at most one citation relationship between two articles (simple graph), (2) if one follows the direction of the citation arcs along any possible path, one cannot visit the same article twice, i.e., there are no circular directed paths (directed acyclic graph). (3) In addition, there is a temporal consistency constraint, e.g., an earlier-published article cannot cite a later-published article.

Shown are six circles labeled alphabetically “A” through “F”. There are 4 arrows connecting some of the circles. The first arrow points from “B” to “D”. The second arrow points from “C” to “D”. The third arrow points from “C” to “E”. The fourth arrow points from “D” to “F”.

### Size and Connectivity of Citation Networks

As mentioned before, we treat these citation networks as operational representations of the clinical evidence base in each nutrient-outcome association. A limited evidence base (in terms of number of articles or number of citation connections between them) may indicate inconsistencies in the findings of several studies, and thus may be encountered in topics where RCT and observational studies disagree. Reciprocally, associations where there is general congruence in the study findings may have many articles and numerous citation connections.

We counted the total number of articles and the total number of citation relationships between articles in the network. These are only a subset of the total counts of citations received by an article. For example, the study on vitamin E and coronary heart disease in men by Rimm et al. 18, received 101 citations within the network but has received more than 1,582 citations in total. We also recorded the number of citations made and number of citations received by each article (calculating density of the citation relationships as per Figure 1), as well as the article’s hub and authority scores. The latter quantify an article’s importance in the citation network. The hub score is higher for articles that cite a lot of other articles (“integrate information”) and are also connected to other articles that also cite a lot of papers. The authority score is higher for articles that receive a lot of citations (i.e., are in some sense “sources of information”) and are also connected to other articles that receive a lot of citations. These metrics convey information on the connectivity of the graph and the relative importance of articles in a network.

### Associations Between Citation Graph Metrics and Qualitative and Quantitative Concordance

We explored whether quantitative characteristics of the citation graphs were associated with qualitative or quantitative concordance, as defined in an earlier paragraph. Specifically, we explored the following characteristics: total number of vertices in the connected graph, total number of citation relationships, mean hub score, mean authority score, mean number of citations made, mean number of citations received, mean number of citations made or received over all the vertices in the graph, and the corresponding mean scores or numbers over the 20 vertices with the highest respective scores or numbers in each graph.

We planned on using proportional odds ordinal logistic regression for the three-category qualitative definition of concordance, and logistic regression for the quantitative definition. However, because no association was qualitatively discordant, we used a logistic regression for the qualitative definition as well. We analyzed one variable at a time, because the small number of available associations did not allow for more complex models. We did not have a sufficiently large sample size to meaningfully evaluate the generalizability of the analyses (e.g., by developing models in a training subset of the dataset and evaluating them in a validation subset).