# Discussion

In this work we provide a large-scale empirical exploration of the hypothesis that the connectivity (in terms of citation relationships) between observational studies and RCTs is associated with the likelihood that the summary findings of these two research designs would agree or disagree. In previous hypothesis forming work we compared quantitative characteristics of the citation maps in one example where the two research designs agree (n−3 polyunsaturated fatty acids and cardiovascular mortality), and in one where they disagree (vitamin E and cardiovascular mortality).12 This larger evaluation shows that depending on the definition of concordance, the summary findings from meta-analyses of observational studies and of RCTs were in qualitative agreement approximately one out of five times (6 out of 34) and were not quantitatively discordant about two thirds of the time (22 out of 34). Despite the variation in the size and the connectivity of the citation graphs across the examined associations, we find no evidence of association between quantitative metrics of the citation graphs and the probability that the two research designs have concordant findings.

The definitions of concordance or discordance used in this work are based on findings from published meta-analyses. Meta-analyses of RCTs and of observational studies are principled systematic syntheses of the totality of the evidence in a given topic, and therefore, it is reasonable and practical to use them as such in meta-epidemiological research. Meta-analyses were used as an operational way to assess a large body of knowledge, but this operationalization necessitates some caveats. Any observed discordance between the results of RCTs and epidemiological studies should not be automatically attributed to the effect of bias, within each study or across studies. Differences in the populations, levels and form of nutrient intakes, and in the exact definitions of the outcomes are alternative explanations, especially if RCTs and epidemiological studies have systematic differences with respect to factors that affect the strength of the association. Conversely, large methodological and epidemiological diversity can lead to substantial statistical heterogeneity, and excessive between-study variability can in make it more difficult to identify discordances between meta-analyses of RCTs and of epidemiological studies.

Research builds on previous findings, and knowledge advances as scientific data and its interpretation are communicated to inform subsequent studies. The generally accepted vehicle for this communication of knowledge is the scientific publication. Therefore, in some sense, the citation networks formed by scientific papers are a representation of the flow of biomedical knowledge through various translational paths, 47 and the analysis of citation networks may provide insights on the size and maturity of the relevant evidence base.

We hypothesized that nutrient associations of disease where RCTs and observational studies agree in the direction and significance of their findings may differ in the size of their evidence base, and the patterns of information flow in it. However, we found no association between the quantitative characteristics of the citation networks and the likelihood of concordance in the examined examples. This negative finding is easy to explain: Only the most dramatic aberrations in a translational path would have been identified in an analysis of citation relationships. An example would be a whole body of literature generated from an unwarranted extrapolation of previous findings.48

There are limitations to using citation analysis to understand translational paths in a given topic. Citing previous research is a complex process. As much as we would like citation practices to be impartial and scientific, they are influenced by personal beliefs, biases and preferences, and are subject to citation distortion. The latter includes citation bias, i.e., when one systematically ignores articles that contain content at odds with ones claims, citation amplification where a lot of citations propagate a belief without any evidence support, and citation invention, that includes citing content but ascribing different meaning to it and converting an hypothesis to fact through citation alone 48. The operational searches used to define the evidence base in each association may have missed early publications that potentially influenced subsequent work, either observational or experimental. We did not assess the methodological quality or the content of the publications in the citation networks, nor did we examine whether any citations made were supportive or dismissive, factual or mistaken, or just providing general context. Publication bias, which occurs as a result of researchers publishing only studies with significant positive results and ignoring studies that report non-significant results, also affects the citation network.

Despite the above limitations, we believe that citation analysis is one of the few representations of the translational process that can be objectively quantified. It merits attention as it can provide a framework to analyze the series of research steps that led to RCTs in humans, and perhaps identify unwarranted extrapolations in the translational process, if any exist 12,48. The examined quantitative characteristics of the citation maps in each association cannot predict the probability that the findings from the two designs agree or disagree. It is unclear whether there is a good way to describe the maturity of the evidence base on an association between nutrients and outcomes. At a minimum, purely bibliometric approaches are not a good way to prioritize which nutrient exposures merit further study, and for which health outcomes.