# Details on the Construction of Citation Graphs

For each of the N papers in each topic (in each corpus), we queried Thompson ISI to obtain a list of its references. We examined these lists to identify which papers are cited by other papers in the corpus, ignoring citations by papers that were not included in the corpus. We organized this information into an adjacency matrix M, i.e., an N × N matrix whose elements m_ij_ code the number of citations (0 or 1) from the j-th to the i-th paper. This matrix contains all the information that is necessary to create the citation graph of the N papers.

In graph theory terminology, citation graphs are directed and acyclic. Directed, because the direction of the arcs is always from the paper that is being cited towards the paper that is making the citation. Acyclic means that there are no closed “loops” in a citation network, because a paper cannot cite itself, and, generally, two or more papers do not cite each other. There are however rare instances where two papers that are, e.g., published in the same issue, cite each other, resulting in a non-acyclic graph. We can transform this graph into a directed graph by assuming that such papers essentially cite each other’s preprints (Appendix Figure 1). This transformation does not affect important characteristics of the networks such as the distributions of in-degrees, authority scores, hub scores, and main path scores (see Glossary).

Appendix Figure 1 Resolving mutual citations to ensure that the citation graph is a simple directed acyclic graph

Left side (a) shows two papers A and B that cite each other. This is a rare occurrence, but can be encountered, e.g., in invited papers published in the same issue. This introduces a closed loop in the citation graph. We resolve this in the right panel (b) by introducing hypothetical preprints of papers A and B (preA, preB, respectively), and assuming that both A and B cite each other’s preprint. The graph on the right (b) is a directed acyclic graph. Because this fix is rarely employed it does not affect the distributions of indegrees, outdegrees, authority scores, hub scores, and main path scores the over the original papers (see glossary for an explanation of terms). This correction can be extended to 3 or more papers.

This figure has two panels. The left panel shows two circles, labeled “A” and “B”, connected by two arrows. One arrow points from circle “A” to circle “B”, and the other points from circle “B” to circle “A”. The right panel shows four circles labeled “preA”, “preB”, “A” and “B”. There are 4 arrows in total in the right panel: the first points from circle “preA” to circle “A”, the second from circle “preA” to circle “B”, the third from circle “preB” to circle “A”, and the fourth from circle “preB” to circle “B”.

Glossary of graph theory and network terms

Term | Description | Example in citation network
Graph | Mathematical construct consisting of vertices or nodes, and edges that connect pairs of vertices. If the edges are directed, the graph is called a directed graph. A directed graph is acyclic when one cannot return to the same vertex following any combination of directed edges. | A citation network graph is a simple directed acyclic graph.
Subgraph | A part of a graph that includes a subset of the vertices and all the edges between them.
Vertex or node | The fundamental unit of a graph. | In a citation network vertices represent papers
Arc or directed edge | A connection between a pair of nodes. It is directed when the order in which the nodes are connected is important. | Arcs go from cited papers (A) to citing papers (B) to denote that some information is flowing from the former to the latter: A→B
Path | A sequence of vertices such that from each vertex there is an edge to the next vertex in the sequence, as if one were visiting vertices by walking a long the edges. In a directed path, the direction of the edges matters, one would be allowed to walk only in the direction of the arcs.
Indegree, outdegree, hub and authority scores | These are measures of the centrality (“importance”) of a paper in a citation network. Indegree is the number of incoming arcs (number of papers cited). Outdegree is the number of outgoing arcs (citations received). Hub and authority scores, is the relative importance of a vertex in a network. A vertex has higher hub or authority score if it has a higher indegree or outdegree respectively, and if it is connected to other vertices with high hub or authority scores respectively. | The distribution of these measures can characterize the connectivity of the citation network, and potentially the amount of information that flows through citations. These measures may identify “key” papers in the corpus of citations.
Temporal consistency | A citation graph is temporally consistent when the cited articles have been published earlier than the corresponding citing articles. | A temporally consistent graph must be acyclic.^*^

* In theory two articles can cite each other. This can happen e.g., in articles appearing in the issue. Such an instance would render the graph non-acyclic (for two papers A and B that cite each other, there is a directed cyclic path: A → B → A).

After correcting for papers that cite each other, we verified that the resulting networks were acyclic, and that there was temporal consistency, i.e., that there were no citations from earlier-published to later-published papers (a paper published in 1979 cannot cite a paper published in 2000).

## Practicalities and Coherency Assessment

We matched citations by exact string matching of titles, after basic preprocessing. Subsequently, we used fuzzy string-matching algorithms (algorithms that tolerate small discrepancies between two title strings) to identify titles that did not match exactly, but pertained to the same paper. This can happen especially for older papers that were entered manually in the Thompson ISI database, because of typos or alternative spelling of title words (e.g., “Randomized trial of …” in MEDLINE may become “Randomized trial of …” in ISI). A human manually reviewed all title pairs that had a Levenshtein edit distance of 5 or less. The results of the manual review were taken into account when forming the final citation graph.

## Main Path Articles

Main paths go from a source vertex to a sink vertex in a citation network, and include vertices and arcs with the highest traversal weights. A source vertex is a vertex that has only outgoing arcs (indegree=0, outdegree>0) and a sink vertex is a vertex that has only incoming arcs (indegree>0, outdegree=0). The traversal weight of a vertex or an arc expresses the proportion of paths from all sources to all sinks in the entire network that include the particular vertex or arc. We calculated transversal weights using the Search Path Link Count (SPLC) method implemented in the Pajek software.1 The results of the SPLC algorithm were very similar to those of alternative methods (vertex pair projection count, VPPC, and search path vertex pair, SPVP). For details on these algorithms and a comparison of their relative performance see the technical report by Batagelj 2003.^1^ One may consider main path articles as central in a field because they integrate information from previous articles (vertices) and propagate information to other articles (vertices).1–5

## References

1 Batagelj V. Efficient algorithms for citation network analysis. 2003. http://arxiv.org/pdf/cs/0309023.pdf. Accessed January 14, 2010.
2 deNooy W, Mrvar A, Batagelj V. Exploratory social network analysis with Pajek. Granovetter M, editor. Structural analysis in the social sciences. New York. Cambridge University Press. 2005.
3 Harris JK, Luke DA, Zuckerman RB, et al. Forty years of secondhand smoke research: the gap between discovery and delivery. Am J Prev Med. Jun. 2009;36(6):538-48. [pmid: 19372026].
4 Hummon N, Doreian P. Computational methods for social network analysis. Social Networks. 1990;12:273-88.
5 Hummon N, Doreian P. Connectivity in a citation network: the development of DNA theory. Social Networks. 1989;11:39-63.