# List of Observational Cohorts and the Screened Publications

## Japan Public Health Center-Based Prospective Study

Akhter M, Inoue M, Kurahashi N, et al. Dietary soy and isoflavone intake and risk of colorectal cancer in the Japan public health center-based prospective study. Cancer Epidemiol Biomarkers Prev. 2008;17:2128-35. [pmid: 18708407].
Ishihara J, Inoue M, Iwasaki M, et al. Dietary calcium, vitamin D, and the risk of colorectal cancer. Am J Clin Nutr. 2008;88:1576-83. [pmid: 19064518].
Ishihara J, Iso H, Inoue M, et al. Intake of folate, vitamin B-6 and vitamin B-12 and the risk of CHD: the Japan Public Health Center-Based Prospective Study Cohort I. J Am Coll Nutr. 2008;27:127-36. [pmid: 18460491].
Ishihara J, Otani T, Inoue M, et al. Low Intake of Vitamin B-6 Is Associated with Increased Risk of Colorectal Cancer in Japanese Men. J Nutr. 2007;137:1808-14. [pmid: 17585035].
Iso H, Kobayashi M, Ishihara J, et al. Intake of fish and n3 fatty acids and risk of coronary heart desease among Japanese. Circulation. 2006;113:195-202. [pmid: 16401768].
Iwasaki M, Inoue M, Otani T, et al. Plasma isoflavone level and subsequent risk of breast cancer among Japanese women: a nested case-control study from the Japan Public Health Center-based Prospective Study Group. J Clin Oncol. 2008;26:1677-83. [pmid: 18316793].
Kim MK, Sasaki S, Sasazuki S, et al. Long-term vitamin C supplementation has no markedly favourable effect on serum lipids in middle-aged Japanese subjects. Br J Nutr. 2004;91:81-90. [pmid: 14748940].
Kim MK, Sasaki S, Sasazuki S, et al. Lack of long-term effect of vitamin C supplementation on blood pressure. Hypertension. 2002;40:797-803. [pmid: 12468560].
Kobayashi M, Sasaki S, Hamada SG, Tsugane S, et al. Serum n-3 fatty acids, fish consumption and cancer mortality in six Japanese populations in Japan and Brazil. Jpn J Cancer Res. 1999;90:914-21. [pmid: 10551318].
Kobayashi M, Tsubono Y, Otani T, et al. Fish, Long-Chain n-3 Polyunsaturated Fatty Acids, and Risk of Colorectal Cancer in Middle-Aged Japanese: The JPHC Study. Nutrition and Cancer. 2004;49:32-40. [pmid: 15456633].
Kokubo Y, Iso H, Ishihara J, et al. Association of Dietary Intake of Soy, Beans and Isoflavones With Risk of Cerebral and Myocardial Infarctions in Japanese Populations: The Japan Public Health Center-Based (JPHC) Study Cohort I. Circulation. 2007;116:2553-62. [pmid: 18025534].
Kurahashi N, Iwasaki M, Inoue M, et al. Plasma isoflavones and subsequent risk of prostate cancer in a nested case-control study: the Japan Public Health Center. J Clin Oncol. 2008;26:5923-9. [pmid: 19018085].
Kurahashi N, Iwasaki M, Sasazuki S, et al. Soy isoflavone consumption is not associated with increased risk of advanced prostate cancer. Cancer Epidemiol Biomarkers Prev. 2007;16:2169. [pmid: 17932370].
Kurahashi N, Iwasaki M, Sasazuki S, et al. Soy product and isoflavone consumption in relation to prostate cancer in Japanese men. Cancer Epidemiol Biomakers Prev. 2007;16:538-45. [pmid: 17337648].
Otani T, Iwasaki M, Ishihara J, et al. Dietary fiber intake and subsequent risk of colorectal cancer: The Japan Public Health Center-Based Prospective Study. Int J Cancer. 2006;119:1475-80. [pmid: 16642466].
Otani T, Iwasaki M, Sasazuki S, et al. Plasma folate and risk of colorectal cancer in a nested case-control study: the Japan Public Health Center-based prospective study. Cancer Causes Control. 2008;19:67-74. [pmid: 17943453].
Otani T, Iwasaki M, Sasazuki S, et al. Plasma vitamin D and risk of colorectal cancer: the Japan Public Health Center-Based Prospective Study. Br J Cancer. 2007;97(3):446-51. [pmid: 17622244].
Persson C, Sasazuki S, Inoue M, et al. Plasma levels of carotenoids, retinol and tocopherol and the risk of gastric cancer in Japan: a nested case-control study. Carcinogenesis. 2008;29:1042-8. [pmid: 18339681].
Sasaki S, Tsubono Y, Okubo S, et al. Effects of three-month oral supplementation of β-carotene and vitamin C on serum concentrations of carotenoids and vitamins in middle-aged subjects:a pilot study for a randomized controlled trial to prevent gastric cancer in high-risk Japanese population. Jpn J Cancer Res. 2000;91:464-70. [pmid: 10835489].
Sasaki S, Yanagibori R. Association between current nutrient intakes and bone mineral density at calcaneus in pre- and postmenopausal Japanese women. J Nutr Sci Vitaminol. 2001;47:289-94. [pmid: 11767209].
Sasazuki S, Hayashi T, Nakachi K, et al. Protective effect of vitamin C on oxidative stress: a randomized controlled trial. Int J Vitam Nutr Res. 2008;78:121-8. [pmid: 19003734].
Sasazuki S, Sasaki S, Tsubono Y, et al. Effect of vitamin C on common cold: radomized controlled trial. Eur J Clin Nutr. 2006;60:9-17. [pmid: 16118650].
Suzuki S, Akechi T, Kobayashi M, et al. Daily omega-3 fatty acid intake and depression in Japanese patients with newly diagnosed lung cancer. Br J Cancer. 2004;90:787-93. [pmid: 14970854].
Takashima Y, Iwase Y, Yoshida M, et al. Relationship of food intake and dietary patterns with blood pressure levels among middle-aged Japanese men. J Epidemiol. 1998;8:106-15. [pmid: 9673080].
Tsubono Y, Kobayashi M, Tsugane S. Food consumption and gastric cancer mortality in five regions of Japan. Nutr Cancer. 1997;27:60-4. [pmid: 8970183].
Tsubono Y, Takahashi T, Iwase Y, et al. Nutrient consumption and gastric cancer mortality in five regions of Japan. Nutr Cancer. 1997;27:310-5. [pmid: 9101562].
Tsubono Y, Tsugane S, Gey F. Plasma antioxidant vitamins and carotenoids in five Japanese populations with varied mortality from gastric cancer. Nutr and Cancer. 1999;34:56-61. [pmid: 10453442].
Umesawa M, Iso H, Ishihara J, et al. Dietary calcium intake and risks of stroke, its subtypes, and coronary heart disease in Japanese: the JPHC Study Cohort I. Stroke. 2008;39:2449-56. [pmid: 18635855].
Yamamoto S, Sobue T, Kobayashi M, et al. Soy, isoflavones, and breast cancer risk in Japan. J Natl Cancer Inst. 2003;95:906-13. [pmid: 12813174].
Yoshida M, Takashima Y, Inoue M, et al. Prospective study showing that dietary vitamin C reduced the risk of age-related cataracts in a middle-aged Japanese. Eur J Nutr. 2007;46:118-24. [pmid: 17265171].

## Nurses’ Health Study

Albert CM, Oh K, Whang W, et al. Dietary alpha-linolenic acid intake and risk of sudden cardiac death and coronary heart disease. Circulation. Nov. 22. 2005;112(21):3232-8. [Abstract]. [pmid: 16301356].
Ascherio A, Hennekens CH, Willett WC, et al. Prospective study of nutritional factors, blood pressure and hypertension among US women. Hypertension. 1996;27:1065-72. [Abstract]. [pmid: 8621198].
Bertone-Johnson ER, Chen WY, Holick MF, et al. Plasma 25-hydroxyvitamin D and 1,25-dihydroxyvitamin D and risk of breast cancer. Cancer Epidemiol Biomarkers Prev. Aug. 2005;14(8):1991-7. [Abstract]. [pmid: 16103450].
Bertone-Johnson ER, Hankinson SE, Bendich A, et al. Calcium and vitamin D intake and risk of incident premenstrual syndrome. Arch Intern Med. 2005;165(11):1246-52. [Abstract]. [pmid: 15956003].
Chasan-Taber L, Willett WC, Seddon JM, et al. A prospective study of vitamin supplement intake and cataract extraction among U.S. women. Epidemiology. 1999;10:679-84. [Abstract]. [pmid: 10535780].
Chasan-Taber L, Willett WC, Seddon JM, et al. A prospective study of carotenoid and vitamin A intakes and risk of cataract extraction in US women. Am J Clin Nutr. 1999;70:509-16. [Abstract]. [pmid: 10500020].
Cho E, Hunter DJ, Spiegelman D, et al. Intakes of vitamins A, C and E and folate and multivitamins and lung cancer: a pooled analysis of 8 prospective studies. Int J Cancer. Feb. 15. 2006;118(4):970-8. [Abstract]. [pmid: 16152626].
Cho E, Smith-Warner SA, Spiegelman D, et al. Dairy foods, calcium, and colorectal cancer: a pooled analysis of 10 cohort studies. J Natl Cancer Inst. 2004;96(13):1015-22. [Abstract]. [pmid: 15240785].
Cho E, Spiegelman D, Hunter DJ, et al. Premenopausal intakes of vitamins A, C, and E, folate, and carotenoids and risk of breast cancer. Cancer Epidemiol Biomarkers Prev. Aug. 2003;12(8):713-20. [Abstract]. [pmid: 12917201].
Cho E, Stampfer MJ, Seddon JM, et al. Prospective study of zinc intake and the risk of age-related macular degeneration. Ann Epidemiol. 2001;11(5):328-36. [Abstract]. [pmid: 11399447].
Costenbader KH, Feskanich D, Benito-Garcia E, et al. Vitamin D intake and risks of systemic lupus erythematosus and rheumatoid arthritis in women. Ann Rheum Dis. 2007;67(4):530-5. Epub 2007. [pmid: 17666449].
Costenbader KH, Feskanich D, Benito-Garcia E, et al. Vitamin D intake and risk of systemic lupus erythematosus and rheumatoid arthritis in women. Ann Rheum Dis. 2008;67:530-5. [Abstract]. [pmid: 17666449].
Curhan GC, Willett WC, Speizer FE, et al. Comparison of dietary with supplemental calcium and other nutrients as factors affecting the risk of kidney stones in women. Ann Int Med. 1997;126:497-504. [Abstract]. [pmid: 9092314].
Curhan GC, Willett WC, Speizer FE, et al. Intake of vitamins B6 and C and the risk of kidney stones in women. J Am Soc Nephrol. 1999;10:840-5. [Abstract]. [pmid: 10203369].
Fairfield KM, Hankinson SE, Rosner BA, et al. Risk of ovarian carcinoma and consumption of vitamins A, C, and E and specific carotenoids: A prospective analysis. Cancer. 2001;92:2318-26. [Abstract]. [pmid: 11745286].
Feskanich D, Ma J, Fuchs CS, et al. Plasma vitamin D metabolites and risk of colorectal cancer in women. Cancer Epidemiol Biomarkers Prev. Sep. 2004;13(9):1502-8. [Abstract]. [pmid: 15342452].
Feskanich D, Singh V, Willett WC, et al. Vitamin A intake and hip fractures among postmenopausal women. JAMA. 2002;287(1):47-54. [Abstract]. [pmid: 11754708].
Feskanich D, Weber P, Willett WC, et al. Vitamin K intake and hip fractures in women: a prospective study. Am J Clin Nutr. 1999;69:74-9. [Abstract]. [pmid: 9925126].
Feskanich D, Willett WC, Colditz GA. Calcium, vitamin D, milk consumption, and hip fractures: a prospective study among postmenopausal women. Am J Clin Nutr. 2003;77:504-11. [Abstract]. [pmid: 12540414].
Feskanich D, Willett WC, Hunter DJ, et al. Dietary intakes of vitamins A, C, and E and risk of melanoma in two cohorts of women. British Journal of Cancer. 2003;88:1381-7. [Abstract]. [pmid: 12778065].
Feskanich D, Willett WC, Stampfer MJ, et al. Milk, dietary calcium, and bone fractures in women: A 12-year prospective study. Am J Public Health. 1997;87:992-7. [Abstract]. [pmid: 9224182].
Forman JP, Bischoff-Ferrari HA, Willett WC, et al. Vitamin D intake and risk of incident hypertension: results from three large prospective cohort studies. Hypertension. 2005;46(4):676-82. [Abstract]. [pmid: 16144983].
Forman JP, Giovannucci E, Holmes MD, et al. Plasma 25-hydroxyvitamin D levels and risk of incident hypertension. Hypertension. May. 2007;49(5):1063-9. [Abstract]. [pmid: 17372031].
Forman JP, Rimm EB, Stampfer MJ, et al. Folate intake and the risk of incident hypertension among US women. JAMA. 2005;293(3):320-9. [Abstract]. [pmid: 15657325].
Fuchs CS, Giovannucci EL, Colditz GA, et al. Dietary fiber and the risk of colorectal cancer and adenoma in women. N Engl J Med. 1999;340:169-76. [Abstract]. [pmid: 9895396].
Fuchs CS, Willett WC, Colditz GA, et al. The influence of folate and multivitamin use on the familial risk of colon cancer in women. Cancer Epidemiol Biomarkers Prev. 2002;11(3):227-34. [Abtract]. [pmid: 11895870].
Fung TT, Hunter DJ, Spiegelman D, et al. Vitamins and carotenoids intake and the risk of basal cell carcinoma of the skin in women (United States). Cancer Causes Control. 2002;13:221-30. [Abstract]. [pmid: 12020103].
Fung TT, Spiegelman D, Egan KM, et al. Vitamin and carotenoid intake and risk of squamous cell carcinoma of the skin. Int J Cancer. 2003;103(1):110-15. [Abstract]. [pmid: 12455062].
Garland M, Morris JS, Colditz GA, et al. Toenail trace elements and breast cancer: a prospective study. Am J Epidemiol. 1996;144:653-60. [Abstract]. [pmid: 8823061].
Garland M, Morris JS, Stampfer MJ, et al. Prospective study of toenail selenium levels and cancer among women. J Natl Cancer Inst. 1995;87:497-505. [Abstract]. [pmid: 7707436].
Giovannucci E, Liu Y, Stampfer MJ, et al. A prospective study of calcium intake and incident and fatal prostate cancer. Cancer Epidemiol Biomarkers Prev. Feb. 2006;15(2):203-10. Abstract 16492906. [pmid: 16492906].
Giovannucci E, Stampfer MJ, Colditz GA, et al. Folate, methionine and alcohol intake and risk of colorectal adenoma. J Natl Cancer Inst. 1993;85:875-84. [Abstract]. [pmid: 8492316].
Giovannucci E, Stampfer MJ, Colditz GA, et al. Multivitamin use, folate, and colon cancer in women in the Nurses’ Health Study. Ann Intern Med. 1998;129:517-24. [Abstract]. [pmid: 9758570].
Grodstein F, Chen J, Willett WC. High-dose antioxidant supplements and cognitive function in community-dwelling elderly women. Am J Clin Nutr. 2003;77(4):975-84. [Abstract]. [pmid: 12663300].
Holick CN, De Vivo I, Feskanich D, et al. Intake of fruits and vegetables, carotenoids, folate, and vitamins A, C, E and risk of bladder cancer among women (United States). Cancer Causes Control. Dec. 2005;16(10):1135-45. [Abstract]. [pmid: 16215863].
Holmes MD, Liu S, Hankinson SE, et al. Dietary carbohydrates, fiber and breast cancer risk. Am J Epidemiol. 2004;159(8):732-9. [Abstract]. [pmid: 15051582].
Hu FB, Bronner L, Willett WC, et al. Fish and omega-3 fatty acid and risk of coronary heart disease in women. JAMA. 2002;287(14):1815-21. [Abstract]. [pmid: 11939867].
Hu FB, Cho E, Rexrode KM, et al. Fish and long-chain omega-3 fatty acid intake and risk of coronary heart disease and total mortality in diabetic women. Circulation. 2003;107:1852-7. [Abstract]. [pmid: 12668520].
Hu FB, Stampfer MJ, Manson JE, et al. Dietary intake of à-linolenic acid and risk of fatal ischemic heart disease among women. Am J Clin Nutr. 1999;69:890-7. [Abstract]. [pmid: 10232627].
Hunter DJ, Manson JE, Colditz GA, et al. A prospective study of intake of vitamins C, E and A and risk of breast cancer. N Engl J Med. 1993;329:234-40. [Abstract]. [pmid: 8292129].
Hunter DJ, Morris JS, Stampfer MJ, et al. A prospective study of selenium status and breast cancer risk. JAMA. 1990;264:1128-31. [Abstract]. [pmid: 2384937].
Iso H, Rexrode KM, Stampfer MJ, et al. Intake of fish and omega-3 fatty acids and risk of stroke in women. JAMA. 2001;285(3):304-12. [Abstract]. [pmid: 11176840].
Iso H, Stampfer MJ, Manson JE, et al. Prospective study of calcium, potassium, and magnesium intake and risk of stroke in women. Stroke. 1999;30:1772-9. [Abstract]. [pmid: 10471422].
Jacques PF, Taylor A, Hankinson SE, et al. Long-term vitamin C supplement use and prevalence of early age-related lens opacities. Am J Clin Nutr. 1997;66:911-6. [Abstract]. [pmid: 9322567].
Kampman E, Giovannucci E, van’t Veer P, et al. Calcium, vitamin D, dairy foods and the occurrence of colorectal adenomas among men and women in two prospective studies. Am J Epidemiol. 1994;139:16-29. [Abstract]. [pmid: 8296771].
Kang JH, Pasquale LR, Willett WC, et al. Antioxidant intake and the risk of primary open-angle glaucoma: a prospective study. Am J Epidemiol. 2003;158(4):337-46. [Abstract]. [pmid: 12915499].
Lee JE, Giovannucci E, Smith-Warner SA, et al. Intakes of fruits, vegetables, vitamins A, C, and E, and carotenoids and risk of renal cell cancer. Cancer Epidemiol Biomarkers Prev. Dec. 2006;15(12):2445-52. [Abstract]. [pmid: 17164369].
Lin J, Zhang SM, Wu K, et al. Flavonoid intake and colorectal cancer risk in men and women. Am J Epidemiol. Oct. 1. 2006;164(7):644-51. [Abstract]. [pmid: 16923774].
Lopez-Ridaura R, Willett WC, Rimm EB, et al. Magnesium intake and risk of type 2 diabetes in men and women. Diabetes Care. 2004;27(1):134-40. [Abstract]. [pmid: 14693979].
Mannisto S, Smith-Warner SA, Spiegelman D, et al. Dietary carotenoids and risk of lung cancer in a pooled analysis of seven cohort studies. Cancer Epidemiol Biomarkers Prev. 2004;13(1):40-8. [Abstract]. [pmid: 14744731].
Männistö S, Yaun SS, Hunter DJ, et al. Dietary carotenoids and risk of colorectal cancer in a pooled analysis of 11 cohort studies. Am J Epidemiol. Feb. 1. 2007;165(3):246-55. [Abstract]. [pmid: 17158857].
Martinez ME, Giovannucci EL, Colditz GA, et al. Calcium, vitamin D, and the occurrence of colorectal cancer among women. J Natl Cancer Inst. 1996;88:1375-82. [Abstract]. [pmid: 8827015].
Munger KL, Zhang SM, O’Reilly E, et al. Vitamin D intake and incidence of multiple sclerosis. Neurology. 2004;62(1):60-5. [Abstract]. [pmid: 14718698].
Neuman MI, Willett WC, Curhan GC. Vitamin and micronutrient intake and the risk of community-acquired pneumonia in US women. Am J Med. Apr. 2007;120(4):330-6. [Abstract]. [pmid: 17398227].
Neuman MI, Willett WC, Curhan GC. Vitamin and micronutrient intake and the risk of community-acquired pneumonia in US women. Am J Med. 2007;120(4):330-6. [pmid: 17398227].
Ng K, Meyerhardt JA, Wu K, et al. Circulating 25-hydroxyvitamin d levels and survival in patients with colorectal cancer. J Clin Oncol. Jun. 20. 2008;26(18):2984-91. (PMC Journal - In Process)[ Abstract]. [pmid: 18565885].
Oh K, Willett WC, Wu K, et al. Calcium and vitamin D intakes in relation to risk of distal colorectal adenoma in women. Am J Epidemiol. May. 15. 2007;165(10):1178-86. [Abstract]. [pmid: 17379616].
Osganian SK, Stampfer MJ, Rimm E, et al. Vitamin C and risk of coronary heart disease in women. J Am Coll Cardiol. 2003;42(2):246-52. [Abstract]. [pmid: 12875759].
Pittas AG, Dawson-Hughes B, Li T, et al. Vitamin D and calcium intake in relation to type 2 diabetes in women. Diabetes Care. Mar. 2006;29(3):650-6. [Abstract]. [pmid: 16505521].
Platz EA, Hankinson SE, Hollis BW, et al. Plasma 1,25-dihydroxy- and 25-hydroxyvitamin D and adenomatous polyps of the distal colorectum. Cancer Epidemiol Biomarkers Prev. 2000;9:1059-65. [Abstract]. [pmid: 11045788].
Rajpathak S, Ma J, Manson J, et al. Iron intake and the risk of type 2 diabetes in women: a prospective cohort study. Diabetes Care. Jun. 2006;29(6):1370-6. [Abstract]. [pmid: 16732023].
Rimm EB, Willett WC, Hu FB, et al. Folate and vitamin B6 from diet and supplements in relation to risk of coronary heart disease among women. JAMA. 1998;279:359-364. [Abstract]. [pmid: 9459468].
Salmer¢n J, Manson JE, Stampfer MJ, et al. Dietary fiber, glycemic load and risk of non-insulin-dependent diabetes mellitus in women. JAMA. 1997;277:472-7. [Abstract]. [pmid: 9020271].
Schernhammer E, Wolpin B, Rifai N, et al. Plasma folate, vitamin B6, vitamin B12, and homocysteine and pancreatic cancer risk in four large cohorts. Cancer Res. Jun. 1. 2007;67(11):5553-60. [Abstract]. [pmid: 17545639].
Shin M-H, Holmes MD, Hankinson SE, et al. Intake of dairy products, calcium, and vitamin D and risk of breast cancer. J Natl Cancer Inst. 2002;94(17):1301-11. [Abstract]. [pmid: 12208895].
Shin MH, Holmes MD, Hankinson SE, et al. Intake of dairy products, calcium, and vitamin D and risk of breast cancer. J Natl Cancer Inst. 2002;94(17):1301-11. [Abstract]. [pmid: 12208895].
Skinner HG, Michaud DS, Giovannucci E, et al. Vitamin D intake and the risk for pancreatic cancer in two cohort studies. Cancer Epidemiol Biomarkers Prev. Sep. 2006;15(9):1688-95. [Abstract]. [pmid: 16985031].
Skinner HG, Michaud DS, Giovannucci EL, et al. A prospective study of folate intake and the risk of pancreatic cancer in men and women. Am J Epidemiol. 2004;160(3):248-58. [Abstract]. [pmid: 15257998].
Stampfer MJ, Hennekens CH, Manson JE, et al. A prospective study of vitamin E consumption and risk of coronary disease in women. N Engl J Med. 1993;328:1444-9. [Abstract]. [pmid: 8479463].
Tamimi RM, Hankinson SE, Campos H, et al. Plasma Carotenoids, Retinol, and Tocopherols and Risk of Breast Cancer. Am J Epidemiol. Jan. 15. 2005;161(2):153-60. [Abstract]. [pmid: 15632265].
Taylor A, Jacques PF, Chylack LT Jr, et al. Long-term intake of vitamins and carotenoids and odds of early age-related cortical and posterior subcapsular lens opacities. Am J Clin Nutr. 2002;75(3):540-9. [Abstract]. [pmid: 11864861].
Tworoger SS, Hecht JL, Giovannucci E, et al. Intake of folate and related nutrients in relation to risk of epithelial ovarian cancer. Am J Epidemiol. Jun. 15. 2006;163(12):1101-11. [Abstract]. [pmid: 16554344].
Tworoger SS, Lee IM, Buring JE, et al. Plasma 25-hydroxyvitamin D and 1,25-dihydroxyvitamin D and risk of incident ovarian cancer. Cancer Epidemiol Biomarkers Prev. Apr. 2007;16(4):783-8. [Abstract]. [pmid: 17416771].
Wei EK, Giovannucci E, Selhub J, et al. Plasma vitamin B6 and the risk of colorectal cancer and adenoma in women. J Natl Cancer Inst. May. 4. 2005;97(9):684-92. [Abstract]. [pmid: 15870439].
Willett WC, Stampfer MJ, Colditz GA, et al. Relation of fat, fiber and meat intake to colon cancer risk in a prospective study among women. N Engl J Med. 1990;323:1669-72. [Abstract]. [pmid: 2172820].
Witteman JCM, Willett WC, Stampfer MJ, et al. A prospective study of nutritional factors and hypertension among U.S. women. Circulation. 1989;80:1320-7. [Abstract]. [pmid: 2805268].
Wolk A, Manson JE, Stampfer MJ, et al. Long-term intake of dietary fiber and decreased risk of coronary heart disease among women. JAMA. 1999;281:1998-2004. [Abstract]. [pmid: 10359388].
Wolpin BM, Wei EK, Ng K, et al. Prediagnostic plasma folate and the risk of death in patients with colorectal cancer. J Clin Oncol. Jul. 1. 2008;26(19):3222-8. [Abstract]. [pmid: 18591557].
Wu K, Feskanich D, Fuchs CS, et al. A nested case control study of plasma 25-hydroxyvitamin D concentrations and risk of colorectal cancer. J Natl Cancer Inst. Jul. 18. 2007;99(14):1120-9. [Abstract]. [pmid: 17623801].
Wu K, Willett WC, Chan JM, et al. A prospective study on supplemental vitamin E intake and risk of colon cancer in women and men. Cancer Epidemiol Biomarkers Prev. 2002;11(11):1298-304. [Abstract]. [pmid: 12433706].
Wu K, Willett WC, Fuchs CS, et al. Calcium intake and risk of colon cancer in women and men. J Natl Cancer Inst. 2002;94(6):437-46. [Abstract]. [pmid: 11904316].
Zhang S, Hunter DJ, Forman MR, et al. Dietary carotenoids and vitamins A, C, and E and risk of breast cancer. J Natl Cancer Inst. 1999;91:547-56. [Abstract]. [pmid: 10088626].
Zhang S, Hunter DJ, Hankinson SE, et al. A prospective study of folate intake and the risk of breast cancer. JAMA. 1999;281:1632-7. [Abstract]. [pmid: 10235158].
Zhang SM, Giovannucci EL, Hunter DJ, et al. Vitamin supplement use and the risk of non-Hodgkin’s lymphoma among women and men. Am J Epidemiol. 2001;153(11):1056-63. [Abstract]. [pmid: 11390323].
Zhang SM, Hankinson SE, Hunter DJ, et al. Folate intake and risk of breast cancer characterized by hormone receptor status. Cancer Epidemiol Biomarkers Prev. Aug. 2005;14(8):2004-8. [Abstract]. [pmid: 16103452].
Zhang SM, Hernan MA, Chen H, et al. Intakes of vitamins E and C, carotenoids, vitamin supplements, and Parkinson’s Disease risk. Neurology. 2002;59(8):1161-9. [Abstract]. [pmid: 12391343].
Zhang SM, Willett WC, Selhub J, et al. Plasma folate, vitamin B6, vitamin B12, homocysteine, and risk of breast cancer. J Natl Cancer Inst. 2003;95:373-80. [Abstract]. [pmid: 12618502].

## Seven-Day Adventist Study

Cho E, Smith-Warner SA, Spiegelman D, et al. Dairy foods, calcium, and colorectal cancer: a pooled analysis of 10 cohort studies. J Natl Cancer Inst. Jul. 7. 2004;96(13):1015-22. [pmid: 15240785].
Genkinger JM, Hunter DJ, Spiegelman D, et al. Dairy products and ovarian cancer: a pooled analysis of 12 cohort studies. Cancer Epidemiol Biomarkers Prev. Feb. 2006;15(2):364-72. [pmid: 16492930].

## The Health Professional Follow-up Study 2009

Al-Delaimy WK, Rimm EB, Willett WC, et al. Magnesium intake and risk of coronary heart disease among men. J Am Coll Nutr. 2004;23:63-70. [pmid: 14963055].
Al-Delaimy WK, Willett WC, Stampfer MJ, et al. A prospective study of calcium intake from diet and supplements and risk of coronary heart disease among men. Am J Clin Nutr. 2003;77:814-8. [pmid: 12663277].
Aldoori WH, Giovannucci EL, Rockett HR, et al. A prospective study of dietary fiber types and symptomatic diverticular disease in men. J Nutr. 1998;128(4):714-9. [pmid: 9521633].
Ascherio A, Rimm EB, Hernan MA, et al. Intake of potassium, magnesium, calcium, and fiber and risk of stroke among US men. Circulation. 1998;98(12):1198-204. [pmid: 9743511].
Ascherio A, Rimm EB, Hernan MA, et al. Relation of consumption of vitamin E, vitamin C, and carotenoids to risk for stroke among men in the United States. Ann Intern Med. 1999;130(12):963-70. [pmid: 10383366].
Brown L, Rimm EB, Seddon JM, et al. A prospective study of carotenoid intake and risk of cataract extraction in US men. Am J Clin Nutr. 1999;70(4):517-24. [pmid: 10500021].
Cho E, Hunter DJ, Spiegelman D, et al. Intakes of vitamins A, C and E and folate and multivitamins and lung cancer: A pooled analysis of 8 prospective studies. Intl J Cancer. 2006;118:970-8. Sep. 8. [Epub ahead of print]. [pmid: 16152626].
Cho E, Smith-Warner SA, Spiegelman D, et al. Dairy foods, calcium, and colorectal cancer: a pooled analysis of 10 cohort studies. 2004;96:1015-22. [pmid: 15240785].
Cho E, Stampfer MJ, Seddon JM, et al. Prospective study of zinc intake and the risk of age-related macular degeneration. Annals Epidemiol. 2001;11(5):328-36. [pmid: 11399447].
Choi HK, Gao X, Curhan G. Vitamin C intake and the risk of gout in men: a prospective study. Arch Intern Med. 2009;169:502-7. [pmid: 19273781].
Curhan GC, Willett WC, Rimm EB, et al. A prospective study of dietary calcium and other nutrients and the risk of symptomatic kidney stones. N Engl J Med. 1993;328(12):833-8. [pmid: 8441427].
Forman JP, Bischoff-Ferrari HA, et al. Vitamin D intake and risk of incident hypertension: results from three large prospective cohort studies. Hypertension. 2005;46:676-682. Epub 2005 Sep 6. [pmid: 16144983].
Forman JP, Choi H, Curhan GC. Fructose and vitamin C intake do not influence risk for developing hypertension. J Am Soc Nephrol. 2009;20:863-71. [pmid: 19144761].
Forman JP, Giovannucci E, Holmes MD, et al. Plasma 25-hydroxyvitamin D levels and risk of incident hypertension. Hypertension. 2007;49(5):1063-9. [pmid: 17372031].
Fung TT, Spiegelman D, Egan KM, et al. Vitamin and carotenoid intake and risk of squamous cell carcinoma of the skin. Int J Cancer. 2003;103(1):110-5. [pmid: 12455062].
Giovannucci E, Liu Y, Hollis BW, et al. 25-hydroxyvitamin D and risk of myocardial infarction in men: a prospective study. Arch Intern Med. 2008;168:1174-80. [pmid: 18541825].
Giovannucci E, Liu Y, Rimm EB, et al. Prospective study of predictors of vitamin D status and cancer incidence and mortality in men. J Natl Cancer Inst. 2006;98:451-9. [pmid: 16595781].
Giovannucci E, Liu Y, Rimm EB, et al. Prospective study of predictors of vitamin D status and cancer incidence and mortality in men. J Natl Cancer Inst. 2006;98:451-9. [pmid: 16595781].
Giovannucci E, Liu Y, Stampfer MJ, et al. A prospective study of calcium intake and incident and fatal prostate cancer. Cancer Epidemiol Biomarkers Prev. 2006;15:203-10. [pmid: 16492906].
Giovannucci E, Liu Y, Willett WC. Cancer incidence and mortality and vitamin D in black and white health professionals. Cancer Epidemiology Biomarkers Prev. 2006;15:2467-72. Epub 2006 Nov 28. [pmid: 17132768].
Giovannucci E, Rimm EB, Wolk A, et al. Calcium and fructose intake in relation to risk of prostate cancer. Cancer Research. 1998;58(3):442-7. [pmid: 9458087].
Giovannucci E, Stampfer MJ, Colditz GA, et al. Folate, methionine and alcohol intake and risk of colorectal adenoma. J Natl Cancer Inst. 1993;85(11):875-84. [pmid: 8492316].
Giovannucci E. Vitamin D and cancer incidence in the Harvard Cohorts. Ann Epidemiol. Feb. 2009;19(2):84-8. [Epub ahead of print 2008 Mar 4]. [pmid: 18291673].
He K, Merchant A, Rimm EB, et al. Folate, vitamin B6 and B12 intakes in relation to risk of stroke among men. Stroke. 2004;35:169-174. [pmid: 14671243].
Kampman E, Giovannucci E, van’t Veer P, et al. Calcium, vitamin D, dairy foods, and the occurrence of colorectal adenomas among men and women in two prospective studies. Am J Epidemiol. 1994;139(1):16-29. [pmid: 8296771].
Kearney J, Giovannucci E, Rimm EB, et al. Calcium, vitamin D and dairy foods and the occurrence of colon cancer in men. Am J Epidemiol. 1996;143(9):907-17. [pmid: 8610704].
Lee JE, Giovannucci E, Smith-Warner SA, et al. Intakes of fruit, vegetables, vitamins A, C, and E, and carotenoids and risk of renal cell cancer. Cancer Epidemiol Biomarkers Prev. 2006;15:2445-52. [pmid: 17164369].
Leitzmann MF, Stampfer MJ, Michaud DS, et al. Dietary intake of n-3 and n-6 fatty acids and the risk of prostate cancer. Am J Clin Nutr. 2004;80:204-16. [pmid: 15213050].
Leitzmann MF, Stampfer MJ, Wu K, et al. Zinc supplement use and risk of prostate cancer. J Natl Cancer Inst. 2003;95:1004-7. [pmid: 12837837].
Lin J, Zhang SM, Wu K, et al. Flavonoid intake and colorectal cancer risk in men and women. Am J Epidemiol. 2006;164:644-51. [pmid: 16923774].
Lopez-Ridaura R, Willett WC, Rimm EB, et al. Magnesium intake and risk of type 2 diabetes in men and women. Diabetes Care. 2004;27:134-40. [pmid: 14693979].
Mannisto S, Smith-Warner SA, Spiegelman D, et al. Dietary carotenoids and risk of lung cancer in a pooled analysis of seven cohort studies. Cancer Epidmiology Biomark Prev. 2004;13:40-8. [pmid: 14744731].
Maserejian NN, Giovannucci E, Rosner B, et al. Prospective study of vitamins C, E., A and carotenoids and risk of oral premalignant lesions in men. Int J Cancer. 2007;120:970-7. [pmid: 17163413].
Merchant AT, Curhan C, Bendich A, et al. Vitamin intake is not associated with community-acquired pneumonia in U.S. men. J Nutr. 2004;134:439-44. [pmid: 14747686].
Merchant AT, Curhan GC, Rimm EB, et al. Intake of n-6 and n-3 fatty acids and fish and risk of community-acquired pneumonia in US men. Am J Clin Nutr. 2005;82:668-74. [pmid: 16155282].
Merchant AT, Hu FB, Spiegelman D, et al. Dietary fiber reduces peripheral arterial disease risk in men. J Nutr. 2003;133:3658-63. [pmid: 14608090].
Michaud DS, Feskanich D, Rimm EB, et al. Intake of specific carotenoids and risk of lung cancer in 2 prospective US cohorts. Am J Clin Nutr. 2000;72(4):990-7. [pmid: 11010942].
Michels KB, Fuchs CS, Giovannucci E, et al. Fiber intake and incidence of colorectal cancer among 76,947 women and 47,279 men. Cancer Epidemiol Biomarkers Prev. 2005;14:842-9. [pmid: 15824154].
Ng K, Meyerhardt JA, Wu K, et al. Circulating 25-hydroxyvitamin D levels and survival in patients with colorectal cancer. J Clin Oncol. 2008;26:2984-91. [pmid: 18565885].
Owusu W, Willett WC, Feskanich D, et al. Calcium intake and the incidence of forearm and hip fractures among men. J Nutr. 1997;127(9):1782-7. [pmid: 9278560].
Park Y, Hunter DJ, Spiegelman D, et al. Dietary fiber intake and risk of colorectal cancer: a pooled analysis of prospective cohort studies. JAMA. 2005;294:2849-57. [pmid: 16352792].
Platz EA, Giovannucci E, Rimm EB, et al. Dietary fiber and distal colorectal adenoma in men. Cancer Epidemiol Biomarkers Prev. 1997;6(9):661-70. [pmid: 9298572].
Platz EA, Leitzmann MF, Hollis BW, et al. Plasma 1,25-dihydroxy- and 25-hydroxyvitamin D and subsequent risk of prostate cancer. Cancer Causes Control. 2004;15:255-65. [pmid: 15090720].
Rajpathak S, Rimm E, Morris JS, et al. Toenail selenium and cardiovascular disease in men with diabetes. J Am Coll Nutr. 2005;24:250-6. [pmid: 16093402].
Rimm EB, Stampfer MJ, Ascherio A, et al. Vitamin E consumption and the risk of coronary heart disease in men. N Engl J Med. 1993;328(20):1450-6. [pmid: 8479464].
Rohrmann S, Giovannucci E, Willett WC, et al. Fruit and vegetable consumption, intake of micronutrients, and benign prostatic hyperplasia in US men. Am J Clin Nutr. 2007;85:523-9. [pmid: 17284753].
Salmeron J, Ascherio A, Rimm EB, et al. Dietary fiber, glycemic load and risk of NIDDM in men. Diabetes Care. 1997;20(4):545-50. [pmid: 9096978].
Schernhammer E, Wolpin B, Rifai N, et al. Plasma folate, vitamin B6, vitamin B12, and homocysteine and pancreatic cancer risk in four large cohorts. Cancer Res. 2007;67:5553-60. [pmid: 17545639].
Skinner HG, Michaud DS, Giovannucci E, et al. Vitamin D intake and the risk for pancreatic cancer in two cohort studies. Cancer Epidemiol Biomarkers Prev. 2006;15:1688-95. [pmid: 16985031].
Skinner HG, Michaud DS, Giovannucci EL, et al. A prospective study of folate intake and the risk of pancreatic cancer in men and women. Am J Epidemiol. 2004;160:248-58. [pmid: 15257998].
Taylor EN, Stampfer MJ, Curhan GC. A prospective study of the intake of vitamins C and B-6 and the risk of kidney stones in men. J Urol. 1996;15(12):1225-32. [pmid: 15579526].
Wolpin BM, Wei EK, Ng K, et al. Prediagnostic plasma folate and the risk of death in patients with colorectal cancer. J Clin Oncol. 2008;26:3222-8. [pmid: 18591557].
Wu K, Erdman JW Jr, Schwartz SJ, et al. Plasma and dietary carotenoids, and the risk of prostate cancer: A nested case-control study. Cancer Epidemiol Biomarkers Prev. 2004;13:260-9. [pmid: 14973107].
Wu K, Feskanich D, Fuchs CS, et al. A nested case control study of plasma 25-hydroxyvitamin D concentrations and risk of colorectal cancer. J Natl Cancer Inst. 2007;99:1120-9. [pmid: 17623801].
Wu K, Willett WC, Chan JM, et al. A prospective study on supplemental E intake and risk of colon cancer in women and men. Cancer Epidemiol Biomark Prev. 2002;11(11):1298-304. [pmid: 12433706].
Wu K, Willett WC, Fuchs CS, et al. Calcium intake and risk of colon cancer in women and men. J Natl Cancer Inst. 2002;94(6):437-46. [pmid: 11904316].
Yoshizawa K, Ascherio A, Morris JS, et al. Prospective study of selenium levels in toenails and risk of coronary heart disease in men. Am J Epidemiol. 2003;158:852-60. [pmid: 14585763].
Yoshizawa K, Willett WC, Morris SJ, et al. Study of prediagnostic selenium level in toenails and the risk of advanced prostate cancer. J Natl Cancer Inst. 1998;90(16):1219-24. [pmid: 9719083].

## The Framingham Heart Study

Abascal VM, Larson MG, Evans JC, et al. Calcium antagonists and mortality risk in men and women with hypertension in the Framingham Heart Study. Arch Intern Med. 1998;158(17):1882-6. [Abstract]. [pmid: 9759683].
Bischoff-Ferrari HA, Zhang Y, Kiel DP, et al. Positive association between serum 25-hydroxyvitamin D level and bone density in osteoarthritis. Arthritis Rheum. 2005;53(6):821-6. [Abstract]. [pmid: 16342101].
Dhingra R, Sullivan LM, Fox CS, et al. Relations of serum phosphorus and calcium levels to the incidence of cardiovascular disease in the community. Arch Intern Med. 2007;167(9):879-85. [Abstract]. [pmid: 17502528].
Felson DT, Niu J, Clancy M, et al. Low levels of vitamin D and worsening of knee osteoarthritis: results of two longitudinal studies. Arthritis Rheum. 2007;56(1):129-36. 445. [Abstract]. [pmid: 17195215].
McAlindon TE, Felson DT, Zhang Y, et al. Relation of dietary intake and serum levels of vitamin D to progression of osteoarthritis of the knee among participants in the Framingham Study. Ann Intern Med. 1996;125(5):353-9. [pmid: 8702085].
McLean RR, Jacques PF, Selhub J, et al. Plasma B vitamins, homocysteine, and their relation with bone loss and hip fracture in elderly men and women. J Clin Endocrinol Metab. 2008;93:2206-12. [pmid: 18364381].
Neogi T, Booth SL, Zhang YQ, et al. Low vitamin K status is associated with osteoarthritis in the hand and knee. Arthritis Rheum. 2006;54(4):1255-61. [ Abstract]. [pmid: 16572460].
Rumawas ME, McKeown NM, Rogers G, et al. Magnesium intake is related to improved insulin homeostasis in the Framingham Offspring cohort. J Am Coll Nutr. Dec. 2006;25(6):486-92. [Abstract]. [pmid: 17229895].
Sahni S, Hannan MT, Gagnon D, et al. High vitamin C intake is associated with lower 4-year bone loss in elderly men. J Nutr. 2008;138:1931-8. [pmid: 18806103].
Schaefer EJ, Bongard V, Beiser AS, et al. Plasma phosphatidylcholine docosahexaenoic acid content and risk of dementia and Alzheimer disease: the Framingham Heart Study. Arch Neurol. Nov. 2006;63(11):1545-50. [Abstract]. [pmid: 17101822].
Troy LM, Jacques PF, Hannan MT, et al. Dihydrophylloquinone intake is associated with low bone mineral density in men and women. Am J Clin Nutr. 2007;86(2):504-8. [Abstract]. [pmid: 17684225].
Tucker KL, Hannan MT, Qiao N, et al. Low plasma vitamin B(12) is associated with lower BMD: The Framingham Osteoporosis Study. J Bone Miner Res. 2005;20(1):152-8. [Abstract]. [pmid: 15619681].
Wang TJ, Pencina MJ, Booth SL, et al. Vitamin D deficiency and risk of cardiovascular disease. Circulation. 2008;117:503-11. [pmid: 18180395].
Yoshida M, Booth SL, Meigs JB, et al. Phylloquinone intake, insulin sensitivity, and glycemic status in men and women. Am J Clin Nutr. 2008;88:210-5. [pmid: 18614743].

## The Iowa Women’s Health Study

Arts ICW, Jacobs DR Jr, Harnack LJ, et al. Dietary catechins in relation to coronary heart disease death among postmenopausal women. Epidemiol. 2001;12:668-75. [pmid: 11679795].
Bostick RM, Kushi LH, Wu Y, et al. Relation of calcium, vitamin D, and dairy food intake to ischemic heart disease mortality among postmenopausal women. Am J Epidemiol. 1999;149:151-61. [pmid: 9921960].
Bostick RM, Potter JD, McKenzie DR, et al. Reduced risk of colon cancer with high intake of Vitamin E: The Iowa Women’s Health Study. Cancer Res. 1993;53:4230-7. [pmid: 8364919].
Bostick RM, Potter JD, Sellers TA, et al. Relation of calcium, vitamin D, and dairy food intake to incidence of colon cancer among older women: The Iowa Women’s Health Study. Am J Epidemiol. 1993;137:1302-17. [pmid: 8333412].
Cerhan JR, Saag KG, Merlino LA, et al. Antioxidant micronutrients and risk of rheumatoid arthritis in a cohort of older women. Am J Epidemiol. 2003;157:345-54. [pmid: 12578805].
Cho E, Hunter DJ, Spiegelman D, et al. Intakes of vitamins A, C, and E and folate and multivitamins and lung cancer: A pooled analysis of 8 prospective studies. Int J Cancer. 2006;118:970-8. [pmid: 16152626].
Cho E, Smith-Warner SA, Spiegelman D, et al. Dairy foods, calcium, and vitamin D and colorectal cancer: A pooled analysis of 10 cohort studies. J Natl Cancer Inst. 2004;96:1015-22. [pmid: 15240785].
Cutler GJ, Nettleton JA, Ross JA, et al. Dietary flavonoid intake and risk of cancer in postmenopausal women: The Iowa Women’s Health Study. Int J Cancer. 2008;123:664-71. [pmid: 18491403].
Folsom AR, Demissie Z. Fish intake, marine omega-3 fatty acids, and mortality in a cohort of postmenopausal women. Am J Epidemiol. 2004;160:1005-10. [pmid: 15522857].
Folsom AR, Hong C-P. Magnesium intake and reduced risk of colon cancer in a prospective study of women. Am J Epidemiol. 2006;163:232-5. [pmid: 16319289].
Harnack L, Jacobs DR Jr, Nicodemus K, et al. Relationship of folate, vitamin B-6, vitamin B-12, and methionine intake to incidence of colorectal cancers. Nutr Cancer. 2002;43:152-8. [pmid: 12588695].
Kelemen LE, Sellers TA, Vierkant RA, et al. Association of folate and alcohol with risk of ovarian cancer in a prospective study of postmenopausal women. Cancer Causes Control. 2004;15:1085-93. [pmid: 15801492].
Koushik A, Hunter DJ, Spiegelman D, et al. Intake of the major carotenoids and the risk of epithelial ovarian cancer in a pooled analysis of 10 cohort studies. Int J Cancer. 2006;119:2148-54. [pmid: 16823847].
Kushi LH, Fee RM, Sellers TA, et al. Intake of vitamins A, C, and E and postmenopausal breast cancer: the Iowa Women’s Health Study. Am J Epidemiol. 1996;144:165-74. [pmid: 8678048].
Kushi LH, Folsom AR, Prineas RJ, et al. Dietary antioxidant vitamins and death from coronary heart disease in postmenopausal women. N Engl J Med. 1996;334:1156-62. [pmid: 8602181].
Kushi LH, Mink PJ, Folsom AR. Antioxidant vitamins, cancer, and cardiovascular disease [Letter to the Editor - Response]. N Engl J Med. 1996;335:1068. [pmid: 8801449].
Lee D-H, Anderson KE, Folsom AR, et al. Heme iron, zinc, and upper digestive tract cancer: The Iowa Women’s Health Study. Int J Cancer. 2005;117:643-7. [pmid: 15929082].
Lee D-H, Anderson KE, Harnack LJ, et al. Heme iron, zinc, alcohol consumption, and colon cancer: Iowa Women’s Health Study. J Natl Cancer Inst. 2004;96:403-7. [pmid: 14996862].
Lee D-H, Folsom AR, Harnack L, et al. Does supplemental vitamin C increase cardiovascular disease risk in women with diabetes?. Am J Clin Nutr. 2004;80:1194-200. [pmid: 15531665].
Lee D-H, Folsom AR, Jacobs DR Jr. Dietary iron intake and type 2 diabetes incidence in postmenopausal women: The Iowa Women’s Health Study. Diabetologia. 2004;47:185-94. [pmid: 14712349].
Lee D-H, Folsom AR, Jacobs DR Jr. Iron, zinc, and alcohol consumption and mortality from cardiovascular diseases: Iowa Women’s Health Study. Am J Clin Nutr. 2005;81:787-91. [pmid: 15817853].
Lee D-H, Jacobs DR Jr. Interaction among heme iron, zinc, and supplemental vitamin C intake on the risk of lung cancer: Iowa Women’s Health Study. Nutr Cancer. 2005;52:130-7. [pmid: 16201844].
Lim LS, Harnack LJ, Lazovich D, et al. Vitamin A intake and the risk of hip fracture in postmenopausal women: the Iowa Women’s Health Study. Osteoporos Int. 2004;15:552-9. [pmid: 14760518].
Männistö S, Smith-Warner SA, Spiegelman D, et al. Dietary carotenoids and risk of lung cancer in a pooled analysis of cohort studies. Cancer Epidemiol Biomarkers Prev. 2004;13:40-8. [pmid: 14744731].
Männistö S, Yaun S-S, Hunter DJ, et al. Dietary carotenoids and risk of colorectal cancer in a pooled analysis of 11 cohort studies. Am J Epidemiol. 2007;165:246-55. [pmid: 17158857].
Merlino LA, Curtis J, Mikuls TR, et al. Vitamin D intake is inversely associated with rheumatoid arthritis: Results from the Iowa Women’s Health Study. Arthritis Rheum. 2004;50:72-7. [pmid: 14730601].
Meyer KA, Kushi LH, Jacobs DR Jr, et al. Carbohydrates, dietary fiber, and incident type 2 diabetes in older women. Am J Clin Nutr. 2000;71:921-30. [pmid: 10731498].
Mink PJ, Scrafford CG, Barraj LM, et al. Flavonoid intake and cardiovascular disease mortality: a prospective study in postmenopausal women. Am J Clin Nutr. 2007;85:895-909. [pmid: 17344514].
Nettleton JA, Harnack LJ, Scrafford CG, et al. Dietary flavonoids and flavonoid-rich foods are not associated with risk of type II diabetes in postmenopausal women. J Nutr. 2006;136:3039-45. [pmid: 17116717].
Park Y, Hunter DJ, Spiegelman D, et al. Dietary fiber intake and risk of colorectal cancer: A pooled analysis of prospective cohort studies. JAMA. 2005;294:2849-57. [pmid: 16352792].
Robien K, Cutler GJ, Lazovich D. Vitamin D intake and breast cancer risk in postmenopausal women: The Iowa Women’s Health Study. Cancer Causes Control. 2007;18:775-82. [pmid: 17549593].
Sellers TA, Alberts SR, Vierkant RA, et al. High folate diets and breast cancer survival in a prospective cohort study. Nutr Cancer. 2002;44:139-44. [pmid: 12734059].
Sellers TA, Kushi LH, Cerhan JR, et al. Dietary folate intake, alcohol, and risk of breast cancer in a prospective study of postmenopausal women. Epidemiology. 2001;12:420-8. [pmid: 11416780].
Sellers TA, Vierkant RA, Cerhan JR, et al. Interaction of dietary folate intake, alcohol, and risk of hormone receptor-defined breast cancer in a prospective study of postmenopausal women. Cancer Epidemiol Biomarkers Prev. 2002;11:1104-7. [pmid: 12376515].
Yochum L, Kushi LH, Meyer K, et al. Dietary flavonoid intake and risk of cardiovascular disease in postmenopausal women. Am J Epidemiol. 1999;149:943-9. [Erratum published in Am J Epidemiol 1999;150(1):3]. [pmid: 10342803].
Yochum LA, Folsom AR, Kushi LH. Dietary flavonoid intake and risk of cardiovascular disease in postmenopausal women [Letter - Reply]. Am J Epidemiol. 2000;151:634-5. [pmid: 10733047].
Yochum LA, Folsom AR, Kushi LH. Intake of antioxidant vitamins and risk of death from stroke in postmenopausal women. Am J Clin Nutr. 2000;72:476-83. [pmid: 10919944].
Zheng W, Anderson KE, Kushi LH, et al. A prospective cohort study of intake of calcium, vitamin D, and other micronutrients in relation to incidence of rectal cancer among postmenopausal women. Cancer Epidemiol Biomarkers Prev. 1998;7:221-5. [pmid: 9521437].

## The Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study

Albanes D, Heinonen OP, Huttunen JK, et al. Effects of alpha-tocopherol and beta-carotene supplements on cancer incidence in the Alpha-Tocopherol Beta-Carotene Cancer Prevention Study. Am J Clin Nutr. 1995;62(6 Suppl):1427S-30S. [pmid: 7495243].
Albanes D, Heinonen OP, Taylor PR, et al. Alpha-Tocopherol and beta-carotene supplements and lung cancer incidence in the alpha-tocopherol, beta-carotene cancer prevention study: effects of base-line characteristics and study compliance. J Natl Cancer Inst. 1996;88(21):1560-70. [pmid: 8901854].
Albanes D, Malila N, Taylor PR, et al. Effects of supplemental alpha-tocopherol and beta-carotene on colorectal cancer: results from a controlled trial (Finland). Cancer Causes Control. 2000;11(3):197-205. [pmid: 10782653].
Bobe G, Weinstein SJ, Albanes D, et al. Flavonoid intake and risk of pancreatic cancer in male smokers (Finland). Cancer Epidemiol Biomarkers Prev. 2008;17(3):553-62. [pmid: 18349272].
Chan JM, Pietinen P, Virtanen M, et al. Diet and prostate cancer risk in a cohort of smokers, with a specific focus on calcium and phosphorus (Finland). Cancer Causes Control. 2000;11(9):859-67. [pmid: 11075876].
Cho E, Hunter DJ, Spiegelman D, et al. Intakes of vitamins A, C and E and folate and multivitamins and lung cancer: a pooled analysis of 8 prospective studies. Int J Cancer. 2006;118(4):970-8. [pmid: 16152626].
Cho E, Smith-Warner SA, Spiegelman D, et al. Dairy foods, calcium, and colorectal cancer: a pooled analysis of 10 cohort studies. J Natl Cancer Inst. 2004;96(13):1015-22. [pmid: 15240785].
Cross AJ, Gunter MJ, Wood RJ, et al. Iron and colorectal cancer risk in the alpha-tocopherol, beta-carotene cancer prevention study. Int J Cancer. 2006. [pmid: 16425287].
Faupel-Badger JM, Diaw L, Albanes D, et al. Lack of association between serum levels of 25-Hydroxyvitamin D and the subsequent risk of prostate cancer in Finnish men. Cancer Epidemiol Biomarkers Prev. 2007;16:2784-6. [pmid: 18086789].
Glynn SA, Albanes D, Pietinen P, et al. Colorectal cancer and folate status: a nested case-control study among male smokers. Cancer Epidemiol Biomarkers Prev. 1996;5(7):487-94. [pmid: 8827351].
Hakkarainen R, Partonen T, Haukka J, et al. Association of dietary amino acids with low mood. Depress Anxiety. 2003;18(2):89-94. [pmid: 12964176].
Hakkarainen R, Partonen T, Haukka J, et al. Is low dietary intake of omega-3 fatty acids associated with depression?. Am J Psychiatry. 2004;161(3):567-9. [pmid: 14992986].
Hartman TJ, Albanes D, Pietinen P, et al. The association between baseline vitamin E, selenium, and prostate cancer in the alpha-tocopherol, beta-carotene cancer prevention study. Cancer Epidemiol Biomarkers Prev. 1998;7(4):335-40. [pmid: 9568790].
Hartman TJ, Taylor PR, Alfthan G, et al. Toenail selenium concentration and lung cancer in male smokers (Finland). Cancer Causes Control. 2002;13(10):923-8. [pmid: 12588088].
Hartman TJ, Woodson K, Stolzenberg-Solomon R, et al. Association of the B-vitamins pyridoxal 5′-phosphate (B(6)), B(12), and folate with lung cancer risk in older men. Am J Epidemiol. 2001;153(7):688-94. [pmid: 11282797].
Heinonen OP, Albanes D, Virtamo J, et al. Prostate cancer and supplementation with alpha-tocopherol and beta-carotene: incidence and mortality in a controlled trial. J Natl Cancer Inst. 1998;90(6):440-6. [pmid: 9521168].
Hemila H, Kaprio J, Albanes D, et al. Vitamin C, vitamin E, and beta-carotene in relation to common cold incidence in male smokers. Epidemiology. 2002;13(1):32-7. [pmid: 11805583].
Hemila H, Kaprio J. Modification of the effect of vitamin E supplementation on the mortality of male smokers by age and dietary vitamin C. Am J Epidemiol. 2009;169(8):946-53. [pmid: 19218294].
Hemila H, Kaprio J. Vitamin E supplementation and pneumonia risk in males who initiated smoking at an early age: effect modification by body weight and dietary vitamin. C Nutr J. 2008;7:33. [pmid: 19019244].
Hemila H, Virtamo J, Albanes D, et al. The effect of vitamin E on common cold incidence is modified by age, smoking and residential neighborhood. J Am Coll Nutr. 2006;25(4):332-9. [pmid: 16943455].
Hemila H, Virtamo J, Albanes D, et al. Vitamin E and beta-carotene supplementation and hospital-treated pneumonia incidence in male smokers. Chest. 2004;125(2):557-65. [pmid: 14769738].
Hirvonen T, Pietinen P, Virtanen M, et al. Intake of flavonols and flavones and risk of coronary heart disease in male smokers. Epidemiology. 2001;12(1):62-7. [pmid: 11138821].
Hirvonen T, Tornwall ME, Pietinen P, et al. Flavonol and flavone intake and the risk of intermittent claudication in male smokers. Eur J Epidemiol. 2004;19(4):305-11. [pmid: 15180100].
Hirvonen T, Virtamo J, Korhonen P, et al. Flavonol and flavone intake and the risk of cancer in male smokers (Finland). Cancer Causes Control. 2001;12(9):789-96. [pmid: 11714106].
Hirvonen T, Virtamo J, Korhonen P, et al. Intake of flavonoids, carotenoids, vitamins C and E, and risk of stroke in male smokers. Stroke. 2000;31(10):2301-6. [pmid: 11022054].
Holick CN, Michaud DS, Stolzenberg-Solomon R, et al. Dietary carotenoids, serum beta-carotene, and retinol and risk of lung cancer in the alpha-tocopherol, beta-carotene cohort study. Am J Epidemiol. 2002;156(6):536-47. [pmid: 12226001].
Huttunen JK, Albanes D, Virtamo J, et al. Antioxidant vitamins and cardiovascular disease mortality: experiences from the Alpha-Tocopherol, Beta-Carotene Lung Cancer Prevention Study. Atherosclerosis. 1995;10:557-9.
Kataja-Tuomola M, Sundell JR, Mannisto S, et al. Effect of alpha-tocopherol and beta-carotene supplementation on the incidence of type 2 diabetes. Diabetologia. 2008;51(1):47-53. [pmid: 17994292].
Knekt P, Ritz J, Pereira MA, et al. Antioxidant vitamins and coronary heart disease risk: a pooled analysis of 9 cohorts. Am J Clin Nutr. 2004;80(6):1508-20. [pmid: 15585762].
Larsson SC, Mannisto S, Virtanen MJ, et al. Dietary fiber and fiber-rich food intake in relation to risk of stroke in male smokers. Eur J Clin Nutr. 2009;63(8):1016-24. [pmid: 19319150].
Larsson SC, Mannisto S, Virtanen MJ, et al. Vitamin B6, Vitamin B12, and Methionine Intakes and Risk of Stroke Subtypes in Male Smokers. Am J Epidemiol. 2008;167(8):954-61. [pmid: 18270369].
Larsson SC, Virtanen MJ, Mars M, et al. Magnesium, calcium, potassium, and sodium intakes and risk of stroke in male smokers. Arch Intern Med. 2008;168(5):459-65. [pmid: 18332289].
Leppala JM, Virtamo J, Fogelholm R, et al. Controlled trial of alpha-tocopherol and beta-carotene supplements on stroke incidence and mortality in male smokers. Arterioscler Thromb Vasc Biol. 2000;20(1):230-5. [pmid: 10634823].
Leppala JM, Virtamo J, Fogelholm R, et al. Vitamin E and beta carotene supplementation in high risk for stroke: a subgroup analysis of the Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study. Arch Neurol. 2000;57(10):1503-9. [pmid: 11030804].
Lim U, Freedman DM, Hollis BW, et al. A prospective investigation of serum 25-hydroxyvitamin D and risk of lymphoid cancers. Int J Cancer. 2009;124(4):979-86. [pmid: 19035445].
Lim U, Weinstein S, Albanes D, et al. Dietary factors of one-carbon metabolism in relation to non-Hodgkin lymphoma and multiple myeloma in a cohort of male smokers. Cancer Epidemiol Biomarkers Prev. 2006;15(6):1109-14. [pmid: 16775167].
Malila N, Taylor PR, Virtanen MJ, et al. Effects of alpha-tocopherol and beta-carotene supplementation on gastric cancer incidence in male smokers (ATBC Study, Finland). Cancer Causes Control. 2002;13(7):617-23. [pmid: 12296509].
Malila N, Virtamo J, Virtanen M, et al. Dietary and serum alpha-tocopherol, beta-carotene and retinol, and risk for colorectal cancer in male smokers. Eur J Clin Nutr. 2002;56(7):615-21. [pmid: 12080400].
Malila N, Virtamo J, Virtanen M, et al. The effect of alpha-tocopherol and beta-carotene supplementation on colorectal adenomas in middle-aged male smokers. Cancer Epidemiol Biomarkers Prev. 1999;8(6):489-93. [pmid: 10385137].
Mannisto S, Pietinen P, Virtanen MJ, et al. Fatty Acids and Risk of Prostate Cancer in a Nested Case-Control Study in Male Smokers. Cancer Epidemiol Biomarkers Prev. 2003;12(12):1422-28. [pmid: 14693732].
Mannisto S, Smith-Warner SA, Spiegelman D, et al. Dietary Carotenoids and Risk of Lung Cancer in a Pooled Analysis of Seven Cohort Studies. Cancer Epidemiol Biomarkers Prev. 2004;13(1):40-8. [pmid: 14744731].
Mannisto S, Yaun SS, Hunter DJ, et al. Dietary carotenoids and risk of colorectal cancer in a pooled analysis of 11 cohort studies. Am J Epidemiol. 2007;165(3):246-55. [pmid: 17158857].
Michaud DS, Pietinen P, Taylor PR, et al. Intakes of fruits and vegetables, carotenoids and vitamins A, E, C in relation to the risk of bladder cancer in the ATBC cohort study. Br J Cancer. 2002;87(9):960-5. [pmid: 12434284].
Mitrou PN, Albanes D, Weinstein SJ, et al. A prospective study of dietary calcium, dairy products and prostate cancer risk (Finland). Int J Cancer. 2007. [pmid: 17278090].
Pereira MA, O’Reilly E, Augustsson K, et al. Dietary fiber and risk of coronary heart disease: a pooled analysis of cohort studies. Arch Intern Med. 2004;164(4):370-6. [pmid: 14980987].
Pietinen P, Ascherio A, Korhonen P, et al. Intake of fatty acids and risk of coronary heart disease in a cohort of Finnish men. The Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study. Am J Epidemiol. 1997;145(10):876-87. [pmid: 9149659].
Rapola JM, Virtamo J, Haukka JK, et al. Effect of vitamin E and beta carotene on the incidence of angina pectoris. A randomized, double-blind, controlled trial. JAMA. 1996;275(9):693-698. [pmid: 8594266].
Rapola JM, Virtamo J, Ripatti S, et al. Effects of alpha tocopherol and beta carotene supplements on symptoms, progression, and prognosis of angina pectoris. Heart. 1998;79(5):454-8. [pmid: 9659191].
Rapola JM, Virtamo J, Ripatti S, et al. Randomised trial of alpha-tocopherol and beta-carotene supplements on incidence of major coronary events in men with previous myocardial infarction. Lancet. 1997;349(9067):1715-20. [pmid: 9193380].
Rautalahti M, Virtamo J, Haukka J, et al. The effect of alpha-tocopherol and beta-carotene supplementation on COPD symptoms. Am J Respir Crit Care Med. 1997;156(5):1447-52. [pmid: 9372659].
Rautalahti MT, Virtamo JR, Taylor PR, et al. The effects of supplementation with alpha-tocopherol and beta-carotene on the incidence and mortality of carcinoma of the pancreas in a randomized, controlled trial. Cancer. 1999;86(1):37-42. [pmid: 10391561].
Stolzenberg-Solomon RZ, Sheffler-Collins S, Weinstein S, et al. Vitamin E intake, alpha-tocopherol status, and pancreatic cancer in a cohort of male smokers. Am J Clin Nutr. 2009;89(2):584-91. [pmid: 19116326].
Stolzenberg-Solomon RZ, Vieth R, Azad A, et al. A prospective nested case-control study of vitamin D status and pancreatic cancer risk in male smokers. Cancer Res. 2006;66(20):10213-9. [pmid: 17047087].
Tangrea J, Helzlsouer K, Pietinen P, et al. Serum levels of vitamin D metabolites and the subsequent risk of colon and rectal cancer in Finnish men. Cancer Causes Control. 1997;8(4):615-25. [pmid: 9242478].
Teikari JM, Virtamo J, Rautalahti M, et al. Long-term supplementation with alpha-tocopherol and beta-carotene and age-related cataract. Acta Ophthalmol Scand. 1997;75(6):634-40. [pmid: 9527321].
The Alpha-Tocopherol Beta Carotene Cancer Prevention Study Group. The effect of vitamin E and beta carotene on the incidence of lung cancer and other cancers in male smokers. N Engl J Med. 1994;330(15):1029-35. [pmid: 8127329].
The ATBC Study Group. Virtamo J, Pietinen P, et al. Incidence of cancer and mortality following alpha-tocopherol and beta-carotene supplementation: a postintervention follow-up. JAMA. 2003;290(4):476-85. [pmid: 12876090].
Tornwall M, Virtamo J, Haukka JK, et al. Effect of alpha-tocopherol (vitamin E) and beta-carotene supplementation on the incidence of intermittent claudication in male smokers. Arterioscler Thromb Vasc Biol. 1997;17(12):3475-80. [pmid: 9437195].
Tornwall ME, Salminen I, Aro A, et al. Effect of serum and dietary fatty acids on the short-term risk of acute myocardial infarction in smoking men. Nutr Metab Cardiovasc Dis. 1996;6:73-80.
Tornwall ME, Virtamo J, Korhonen PA, et al. Postintervention effect of alpha tocopherol and beta carotene on different strokes: a 6-year follow-up of the Alpha Tocopherol, Beta Carotene Cancer Prevention Study. Stroke. 2004;35(8):1908-13. [pmid: 15205487].
Tornwall ME, Virtamo J, Korhonen PA, et al. Effect of alpha-tocopherol and beta-carotene supplementation on coronary heart disease during the 6-year post-trial follow-up in the ATBC study. Eur Heart J. 2004;25(13):1171-8. [pmid: 15231376].
Varis K, Taylor PR, Sipponen P, et al. Gastric cancer and premalignant lesions in atrophic gastritis: a controlled trial on the effect of supplementation with alpha-tocopherol and beta-carotene. The Helsinki Gastritis Study Group. Scand J Gastroenterol. 1998;33(3):294-300. [pmid: 9548624].
Virtamo J, Edwards BK, Virtanen M, et al. Effects of supplemental alpha-tocopherol and beta-carotene on urinary tract cancer: incidence and mortality in a controlled trial (Finland). Cancer Causes Control. 2000;11(10):933-9. [pmid: 11142528].
Virtamo J, Rapola JM, Ripatti S, et al. Effect of vitamin E and beta carotene on the incidence of primary nonfatal myocardial infarction and fatal coronary heart disease. Arch Intern Med. 1998;158(6):668-75. [pmid: 9521232].
Watters JL, Gail MH, Weinstein SJ, et al. Associations between alpha-tocopherol, beta-carotene, and retinol and prostate cancer survival. Cancer Research. 2009;69(9):3833-41. [pmid: 19383902].
Weinstein SJ, Hartman TJ, Stolzenberg-Solomon R, et al. Null association between prostate cancer and serum folate, vitamin B(6), vitamin B(12), and homocysteine. Cancer Epidemiol Biomarkers Prev. 2003;12(11 Pt 1):1271-2. [pmid: 14652294].
Weinstein SJ, Stolzenberg-Solomon R, Pietinen P, et al. Dietary factors of one-carbon metabolism and prostate cancer risk. Am J Clin Nutr. 2006;84(4):929-35. [pmid: 17023722].
Weinstein SJ, Wright ME, Lawson KA, et al. Serum and dietary vitamin E in relation to prostate cancer risk. Cancer Epidemiol Biomarkers Prev. 2007;16(6):1253-9. [pmid: 17548693].
Weinstein SJ, Wright ME, Pietinen P, et al. Serum alpha-tocopherol and gamma-tocopherol in relation to prostate cancer risk in a prospective study. J Natl Cancer Inst. 2005;97(5):396-9. [pmid: 15741576].
Wilson RT, Wang J, Chinchilli V, et al. Fish, vitamin D, and flavonoids in relation to renal cell cancer among smokers. Am J Epidemiol. 2009;170(6):717-29. [pmid: 19651663].
Woodson K, Tangrea JA, Barrett MJ, et al. Serum alpha-tocopherol and subsequent risk of lung cancer among male smokers. J Natl Cancer Inst. 1999;91(20):1738-43. [pmid: 10528024].
Wright ME, Lawson KA, Weinstein SJ, et al. Higher baseline serum concentrations of vitamin E are associated with lower total and cause-specific mortality in the Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study. Am J Clin Nutr. 2006;84(5):1200-7. [pmid: 17093175].
Wright ME, Virtamo J, Hartman AM, et al. Effects of alpha-tocopherol and beta-carotene supplementation on upper aerodigestive tract cancers in a large, randomized controlled trial. Cancer. 2007;109(5):891-8. [pmid: 17265529].

## Honolulu Heart Study

Abbott RD, Ando F, Masaki KH, et al. Dietary magnesium intake and the future risk of coronary heart disease (the Honolulu Heart Program). Am J Cardiol. Sep. 15. 2003;92(6):665-9. [pmid: 12972103].
Abbott RD, Curb JD, Rodriguez BL, et al. Effect of dietary calcium and milk consumption on risk of thromboembolic stroke in older middle-aged men. The Honolulu Heart Program. Stroke. May. 1996;27(5):813-8. [pmid: 8623098].
Joffres MR, Reed DM, Yano K. Relationship of magnesium intake and other dietary factors to blood pressure: the Honolulu heart study. Am J Clin Nutr. Feb. 1987;45(2):469-75. [pmid: 3812346].
Laurin D, Foley DJ, Masaki KH, et al. Vitamin E and C supplements and risk of dementia. JAMA. Nov. 13. 2002;288(18):2266-8. No abstract available. [pmid: 12425703].

## Netherlands Cohort Study on Diet and Cancer

Brink M, Weijenberg MP, de Goeij AF, et al. Dietary folate intake and k-ras mutations in sporadic colon and rectal cancer in The Netherlands Cohort Study. Int J Cancer. 2005;114(5):824-30. [pmid: 15609319].
de Vogel S, Dindore V, van Engeland M, et al. Dietary folate, methionine, riboflavin, and vitamin B-6 and risk of sporadic colorectal cancer. J Nutr. 2008;138(12):2372-8. [pmid: 19022960].
de Vogel S, van Engeland M, Luchtenborg M, et al. Dietary folate and APC mutations in sporadic colorectal cancer. J Nutr. 2006;136(12):3015-21. [pmid: 17116713].
Keszei AP, Verhage BA, Heinen MM, et al. Dietary folate and folate vitamers and the risk of pancreatic cancer in the Netherlands cohort study. Cancer Epidemiol Biomarkers Prev. 2009;18(6):1785-91. [pmid: 19505911].
van den Brandt PA, Smits KM, Goldbohm RA, et al. Magnesium intake and colorectal cancer risk in the Netherlands Cohort Study. British Journal of Cancer. 2007;96(3):510-3. [pmid: 17285123].
van Dijk BA, Schouten LJ, Oosterwijk E, et al. Carotenoid and vitamin intake, von Hippel-Lindau gene mutations and sporadic renal cell carcinoma. Cancer Causes & Control. 2008;19(2):125-34. [pmid: 17992578].
Voorrips LE, Brants HA, Kardinaal AF, et al. Intake of conjugated linoleic acid, fat, and other fatty acids in relation to postmenopausal breast cancer: the Netherlands Cohort Study on Diet and Cancer. Am J Clin Nutr. 2002;76(4):873-82. [pmid: 12324303].
Voorrips LE, Goldbohm RA, Brants HA, et al. A prospective cohort study on antioxidant and folate intake and male lung cancer risk. Cancer Epidemiol Biomarkers Prev. 2000;9(4):357-65. [pmid: 10794479].

## The Singapore Chinese Health Study

Karlson EW, Shadick NA, Cook NR, et al. Vitamin E in the primary prevention of rheumatoid arthritis: the Women’s Health Study. Arthritis Rheum. Nov. 15. 2008;59(11):1589-95. [pmid: 18975365].
Lee IM, Cook NR, Gaziano JM, et al. Vitamin E in the primary prevention of cardiovascular disease and cancer: the Women’s Health Study: a randomized controlled trial. JAMA. Jul. 6. 2005;294(1):56-65. [pmid: 15998891].
Lee IM, Cook NR, Manson JE, et al. Beta-carotene supplementation and incidence of cancer and cardiovascular disease: the Women’s Health Study. J Natl Cancer Inst. Dec. 15. 1999;91(24):2102-6. [pmid: 10601381].
Lee IM, Cook NR, Manson JE, et al. Randomised beta-carotene supplementation and incidence of cancer and cardiovascular disease in women: is the association modified by baseline plasma level?. Br J Cancer. Mar. 4. 2002;86(5):698-701. [pmid: 11875728].
Lin J, Zhang SM, Cook NR, et al. Intakes of calcium and vitamin D and risk of colorectal cancer in women. Am J Epidemiol. Apr. 15. 2005;161(8):755-64. [pmid: 15800268].
Liu S, Buring JE, Sesso HD, et al. A prospective study of dietary fiber intake and risk of cardiovascular disease among women. J Am Coll Cardiol. Jan. 2. 2002;39(1):49-56. [pmid: 11755286].
Sesso HD, Buring JE, Norkus EP, et al. Plasma lycopene, other carotenoids, and retinol and the risk of cardiovascular disease in women. Am J Clin Nutr. Jan. 2004;79(1):47-53. [pmid: 14684396].
Sesso HD, Gaziano JM, Liu S, et al. Flavonoid intake and the risk of cardiovascular disease in women. Am J Clin Nutr. Jun. 2003;77(6):1400-8. [pmid: 12791616].
Song Y, Manson JE, Buring JE, et al. Dietary magnesium intake in relation to plasma insulin levels and risk of type 2 diabetes in women. Diabetes Care. Jan. 2004;27(1):59-65. [pmid: 14693967].
Song Y, Ridker PM, Manson JE, et al. Magnesium intake, C-reactive protein, and the prevalence of metabolic syndrome in middle-aged and older U.S. women. Diabetes Care. Jun. 2005;28(6):1438-44. [pmid: 15920065].

## Norwegian Mother & Child Cohort Study

Håberg SE, London SJ, Stigum H, et al. Folic acid supplements in pregnancy and early childhood respiratory health. Archives of Disease in Childhood. Mar. 2009;94(3):180-4. Epub 2008 Dec 3. [pmid: 19052032].
Nilsen RM, Vollset SE, Monsen ALB, et al. Second trimester folate exposures and smoking in relation to infant birth size: prospective cohort. Submitted.

## European Prospective Investigation into Diet and Cancer Study

Bingham SA, Day NE, Luben R, et al. Dietary fibre in food and protection against colorectal cancer in the European Prospective Investigation into Cancer and Nutrition (EPIC): an observational study. Lancet. 2003;361(9368):1496-501. [pmid: 12737858].
Chajes V, Thiebaut AC, Rotival M, et al. Association between serum trans-monounsaturated fatty acids and breast cancer risk in the E3N-EPIC study. Am J Epidemiol. 2008. [pmid: 18390841].
Dalmeijer GW, Olthof MR, Verhoef P, et al. Prospective study on dietary intakes of folate, betaine, and choline and cardiovascular disease risk in women. Eur J Clin Nutr. 2008;62(3):386-94. [Abstract]. [pmid: 17375117].
Franco OH, Burger H, Lebrun CE, et al. Higher dietary intake of lignans is associated with better cognitive performance in postmenopausal women. J Nutr. 2005;135(5):1190-5. [Abstract]. [pmid: 15867302].
Frost L, Vestergaard P. n-3 Fatty acids consumed from fish and risk of atrial fibrillation or flutter: the Danish Diet, Cancer, and Health Study. Am J Clin Nutr. 2005;81(1):50-4. [Abstract]. [pmid: 15640459].
Iannuzzi A, Celentano E, Panico S, et al. Dietary and circulating antioxidant vitamins in relation to carotid plaques in middle-aged women. Am J Clin Nutr. 2002;76(3):582-7. [Abstract]. [pmid: 12198003].
Jenab M, Riboli E, Ferrari P, et al. Plasma and dietary vitamin C levels and risk of gastric cancer in the European Prospective Investigation into Cancer and Nutrition (EPIC-EURGAST). Carcinogenesis. 2006;27(11):2250-7. [Abstract]. [pmid: 16774936].
Johansson M, Appleby PN, Allen NE, et al. Circulating concentrations of folate and vitamin B12 in relation to prostate cancer risk: results from the European prospective investigation into cancer and nutrition study. Cancer Epidemiol Biomarkers Prev. 2008;17(2):279-85. [pmid: 18268110].
Kesse E, Boutron-Ruault MC, Norat T, et al. Dietary calcium, phosphorus, vitamin D, dairy products and the risk of colorectal adenoma and cancer among French women of the E3N-EPIC prospective study. Int J Cancer. 2005;117(1):137-44. [Abstract]. [pmid: 15880532].
Key TJ, Appleby PN, Allen NE, et al. Plasma carotenoids, retinol, and tocopherols and the risk of prostate cancer in the European Prospective Investigation into Cancer and Nutrition study. Am J Clin Nutr. 2007;86(3):672-81. [pmid: 17823432].
Khaw KT, Bingham S, Welch A, et al. Relation between plasma ascorbic acid and mortality in men and women in EPIC-Norfolk prospective study: a prospective population study. European Prospective Investigation into Cancer and Nutrition. Lancet. 2001;357(9257):657-63. [Abstract]. [pmid: 11247548].
Lajous M, Romieu I, Sabia S, et al. Folate, vitamin B12 and postmenopausal breast cancer in a prospective study of French women. Cancer Causes Control. 2006;17(9):1209-13. [Abstract]. [pmid: 17006726].
Luben R, Khaw KT, Welch A, et al. Plasma vitamin C, cancer mortality and incidence in men and women: a prospective study. IARC Sci Pub. 2002;156:117-8. [pmid: 12484141].
Ma M, Pera G, Agudo A, et al. Cereal fiber intake may reduce risk of gastric adenocarcinomas: The EPIC-EURGAST study. Int J Cancer. 2007. [Abstract]. [pmid: 17582605].
Nimptsch K, Rohrmann S, Linseisen J. Dietary intake of vitamin K and risk of prostate cancer in the Heidelberg cohort of the European Prospective Investigation into Cancer and Nutrition (EPIC-Heidelberg). Am J Clin Nutr. 2008;87(4):985-92. [pmid: 18400723].
Nissen SB, Tjonneland A, Stripp C, et al. Intake of vitamins A, C, and E from diet and supplements and breast cancer in postmenopausal women. Cancer Causes Control. 2003;14(8):695-704. [pmid: 14674733].
Park Y, Hunter DJ, Spiegelman D, et al. Dietary fiber intake and risk of colorectal cancer: a pooled analysis of prospective cohort studies. JAMA. 2005;294(22):2849-57. [pmid: 16352792].
Pattison DJ, Silman AJ, Goodson NJ, et al. Vitamin C and the risk of developing inflammatory polyarthritis: prospective nested case-control study. Ann Rheum Dis. 2004;63(7):843-7. [pmid: 15194581].
Roddam AW, Neale R, Appleby P, et al. Association between plasma 25-hydroxyvitamin D levels and fracture risk: The EPIC-Oxford Study. Am J Epidemiol. 2007. [Abstract]. [pmid: 17716981].
Sargeant LA, Wareham NJ, Bingham S, et al. Vitamin C and hyperglycemia in the European Prospective Investigation into Cancer—Norfolk (EPIC-Norfolk) study: a population-based study. Diabetes Care. 2000;23(6):726-32. [Abstract]. [pmid: 10840986].
Touvier M, Kesse E, Clavel-Chapelon F, et al. Dual Association of beta-carotene with risk of tobacco-related cancers in a cohort of French women. J Natl Cancer Inst. 2005;97(18):1338-44. [Abstract]. [pmid: 16174855].
van der AD, Peeters PH, Grobbee DE, et al. Dietary haem iron and coronary heart disease in women. Eur Heart J. 2004. [Abstract]. [pmid: 15618055].
Wirfalt E, Mattisson I, Gullberg B, et al. Postmenopausal breast cancer is associated with high intakes of omega6 fatty acids (Sweden). Cancer Causes Control. 2002;13(10):883-93. [Abstract]. [pmid: 12588084].

## NIH-AARP Diet and Health Study

Schatzkin A, Mouw T, Park Y, et al. Dietary fiber and whole grain consumption in relation to colorectal cancer in the NIH-AARP Diet and Health Study. Am J Clin Nutr. 2007;85:1353-60. [pmid: 17490973].
Schatzkin A, Park Y, Leitzmann MF, et al. Prospective study of dietary fiber, whole grains, and small intestinal cancer. Gastroenterology. 2008;135(4):1163-7. [pmid: 18727930].
Terry P, Jain M, Miller A, et al. Dietary carotenoid intake and colorectal cancer risk. Nutrition & Cancer. 2002;42(2):167-72. [pmid: 12416255].
Terry P, Jain M, Miller AB, et al. Dietary carotenoids and risk of breast cancer. Am J Clin Nutr. 2002;76(4):883-8. [pmid: 12324304].
Wright ME, Weinstein SJ, Lawson KA, et al. Supplemental and dietary vitamin E intakes in relation to prostate cancer incidence and mortality in a large prospective study. Cancer Epidemiol Biomarker Prev. 2007;16(6):1128-35.

## Dietary Intake of Folic Acid and Colorectal Cancer Risk in a Cohort of Women

Rohan TE, Howe GR, Friedenreich CM, et al. Dietary fiber, vitamins A, C, and E, and risk of breast cancer: a cohort study. Cancer Causes & Control. 1993;4(1):29-37. [pmid: 8381678].
Simard A, Vobecky J, Vobecky JS. Vitamin D deficiency and cancer of the breast: an unprovocative ecological hypothesis. Canadian Journal of Public Health. Revue Canadienne de Sante Publique. Sep-Oct. 1991;82(5):300-3. [pmid: 1768986].
Terry P, Jain M, Miller AB, et al. Dietary intake of folic acid and colorectal cancer risk in a cohort of women. Int J Cancer. 2002;97(6):864-7. [pmid: 11857369].

## The Danish Diet, Cancer and Health Study

Collaborative Group on Prospective Studies of Diet and Cancer. McCullough M. collaborator. Dietary fiber intake and risk of colorectal cancer: a pooled analysis of prospective cohort studies. JAMA. 2005;294:2849-57. [pmid: 16352792].
McCullough M, Robertson AS, Rodriguez C, et al. Calcium, vitamin D, dairy products and risk of colorectal cancer in the Cancer Prevention Study II Nutrition Cohort. Cancer Causes Control. 2003;14:1-12. [pmid: 12708719].
McCullough ML, Rodriguez C, Diver WR, et al. Dairy, calcium, and vitamin D intake and postmenopausal breast cancer in the Cancer Prevention Study II Nutrition Cohort. Cancer Epidemiol Biomarkers Prev. 2005;14(12):1-7. [pmid: 16365007].
Pooling Project of Prospective Studies of Diet and Cancer. McCullough ML, Rodriguez C. Intake of the major carotenoids and the risk of epithelial ovarian cancer in a pooled analysis of 10 cohort studies. Int J Cancer. 2006;119(9):2148-54. [pmid: 16823847].
Rodriguez C, Jacobs EJ, Mondul AM, et al. Vitamin E supplements and risk of prostate cancer in U.S. men. Cancer Epidemiol Biomark Prev. 2004;13(3):378-82. [pmid: 15006912].
Rodriguez C, McCullough M, Mondul A, et al. Calcium, dairy products, and risk of prostate cancer in a prospective cohort of U.S. men. Cancer Epidemiol Biomarkers Prev. 2003;12:597-603. [pmid: 12869397].
Stevens VL, Rodriguez C, Pavluck AL, et al. Folate nutrition and prostate cancer incidence in a large cohort of US men. Am J Epidemiol. 2006;163:989-96. [pmid: 16554345].

## Women’s Health Initiative

Caire-Juvera G, Ritenbaugh C, Wactawski-Wende J, et al. Vitamin A and retinol intakes and the risk of fractures among participants of the Women’s Health Initiative observational study. Am J Clin Nutr. 2008. Dec. 3. [pmid: 19056568].
Cauley JA, LaCroix AZ, Wu L, et al. Serum 25-hydroxyvitamin D concentrations and risk for hip fractures. Ann Intern Med. Aug. 2008;149(4):242-50. [pmid: 18711154].
Chlebowski RT, Johnson KC, Kooperberg C, et al. Calcium plus vitamin D supplementation and the risk of breast cancer. J Natl Cancer Inst. Nov. 19. 2008;100(22):1581-91. [pmid: 19001601].
Cui Y, Shikany JM, Liu S, et al. Selected antioxidants and risk of hormone receptor-defined invasive breast cancers among postmenopausal women in the Women’s Health Initiative observational study. Am J Clin Nutr. Apr. 2008;87(4):1009-18. [pmid: 18400726].
de Boer IH, Kestenbaum B, Siscovick DS, et al. Calcium plus vitamin D supplementation and the risk of incident diabetes mellitus in the Women’s Health Initiative. Diabetes Care. 2008. Jan. 30. Epub. [pmid: 18235052].
Hsia J, Heiss G, Ren H, et al. Calcium/vitamin D supplementation and cardiovascular events. Circulation. 2007;115:846-54. [pmid: 17309935].
Jackson RD, LaCroix AZ, Gass M, et al. The Women’s Health Initiative trial of calcium plus vitamin D supplementation on risk for fractures. NEJM. 2006;354:669-83. [pmid: 16481635].
Margolis KL, Ray RM, Van Horn L, et al. Effect of calcium and vitamin D supplementation on blood pressure: the Women’s Health Initiative randomized trial. Hypertension. Nov. 2008;52:847-55. [pmid: 18824662].
Rohan TE, Negassa A, Chlebowski RT, et al. A randomized controlled trial of calcium plus vitamin D supplementation and risk of benign proliferative breast disease. Breast Cancer Res Treat. 2008. Oct. 14. [Epub ahead of print]. [pmid: 18853250].
Schernhammer E, Wolpin B, Rifai N, et al. Plasma folate, vitamin B6, vitamin B12, and homocysteine and pancreatic cancer risk in four large cohorts. Cancer Res. Jun. 1. 2007;67(11):5553-60. [pmid: 17545639].
Thomson CA, Neuhouser ML, Shikany JM, et al. The role of antioxidants and vitamin A in ovarian cancer: results from the Women’s Health Initiative. Nutr Cancer. 2008;60(6):710-9. [pmid: 19005970].
Wactawski-Wende J, Kotchen JM, Anderson GL, et al. Calcium and vitamin D supplementation and colorectal cancer in postmenopausal women: the Women’s Health Initiative clinical trial. NEJM. 2006;354:684-96. [pmid: 16481636].

## Swedish Mammography Cohort Study

Ahn J, Peters U, Albanes D, et al. Serum Vitamin D concentration and prostate cancer risk: A nested case-control study. J Natl Cancer Inst. 2008;100(11):796-804. [Abstract]. [pmid: 18505967].
Freedman DM, Chang SC, Falk RT, et al. Serum levels of vitamin D metabolites and breast cancer risk in the Prostate, Lung Colorectal and Ovarian Cancer Screening Trial. Cancer Epidemiology, Biomarkers & Prev. 2008;17(4):889-94. [Abstract] [Full Text]. [pmid: 18381472].
Jumaan AO, Holmberg L, Zack M, et al. Beta-carotene intake and risk of postmenopausal breast cancer. Epidemiology. 1999;10:49-53. [pmid: 9888279].
Kirsh VA, Hayes RB, Mayne ST, et al. Supplemental and dietary vitamin E, beta carotene, and vitamin C intakes and prostate cancer risk. J Natl Cancer Inst. 2006;98(4):245-54. [Abstract]. [pmid: 16478743].
Koralek DO, Peters U, Andriole G, et al. A prospective study of dietary alpha-linolenic acid and the risk of prostate cancer (United States). Cancer Causes Control. 2006;17:783-791. [pmid: 16783606].
Larsson SC, Bergkvist L, Wolk A. Magnesium Intake in relation to risk of colorectal cancer in women. JAMA. 2005;293:86-9. [pmid: 15632340].
Larsson SC, Giovanucci E, Wolk A. Dietary folate intake and incidence of ovarian cancer: The Swedish Mammography Cohort. J Natl Cancer Inst. 2004;96:396-402. [pmid: 14996861].
Melhus H, Michalsson K, Kindmark A, et al. Excessive dietary intake of vitamin A is associated with reduced bone mineral density and increased risk for hip fracture. Ann Intern Med. 1998;129:770-8. [pmid: 9841582].
Michalsson K, Melhus H, Bellocco R, et al. Dietary calcium and vitamin D intake in relation to osteoporotic fracture risk. Bone. 2003;32:694-703. [pmid: 12810177].
Michels KB, Holmberg L, Bergkvist L, et al. Dietary antioxidant vitamins, retinol, and breast cancer incidence in a cohort of Swedish women. Int J Cancer. Feb. 15. 2001;91(4):563-7. [pmid: 11251982].
Oaks BM, Dodd KW, Meinhold CL, et al. Folate intake, post-folic acid grain fortifiation, and pancreatic cancer risk in the Prostate, Lung, Colorectal, and Ovarian Cancer Screeing Trial. Am J Clin Nutr. 2009. Epub ahead of print. [Abstract]. [pmid: 20007302].
Peters U, Chatterjee N, McGlynn KA, et al. Calcium intake and colorectal adenoma in a US colorectal cancer early detection program. Am J Clin Nutr. 2004;80:1358-65. [Abstract] [Full Text]. [pmid: 15531687].
Peters U, Chatterjee N, Church TR, et al. High serum selenium and reduced risk of advanced colorectal adenoma in a colorectal cancer early detection program. Cancer Epidemiology Biomarkers Prevention. 2006;15(2):315-20. [Abstract] [Full Text]. [pmid: 16492922].
Peters U, Foster CB, Chatterjee N, et al. Serum selenium and risk of prostate cancer - a nested case-control study. Am J Clin Nutr. 2007;85(1):209-17. [pmid: 17209198].
Peters U, Leitzmann MF, Chatterjee N, et al. Serum lycopene, other carotenoids, and prostate cancer risk: a nested case-control study in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. Cancer Epidemiology Biomarkers and Prevention. 2007;16(5):962-8. [pmid: 17507623].
Peters U, Sinha R, Chatterjee N, et al. Dietary fibre and colorectal adenoma in a colorectal cancer early detection programme. The Lancet. 2003;361:1491-5. [pmid: 12737857].
Schenk JM, Riboli E, Chatterjee N, et al. Serum retinol and prostate cancer risk: A nested case-control study in the Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial. Cancer Epidemiology Biomarkers & Prevention. 2009;18(4):1227-31. [pmid: 19336558].
Stolzenberg-Solomon RZ, Hayes RB, Horst RL, et al. Serum vitamin D and risk of pancreatic cancer in the prostate, lung, colorectal, and ovarian screening trial. Cancer Research. 2009;69(4):1439-47. [Abstract] [Full Text]. [pmid: 19208842].
Terry P, Baron JA, Bergkvist L, et al. Dietary calcium and vitamin D intake and risk of colorectal cancer: a prospective cohort study in women. Nutr Cancer. 2002;43:39-46. [pmid: 12467133].
Wolk A, Bergström R, Hunter D, et al. A prospective study of association of monounsaturated fat and other types of fat with risk of breast cancer. Arch Intern Med. Jan. 12. 1998;158(1):41-5. [pmid: 9437377].

## Multiethnic Cohort Study

Kan H, Stevens J, Heiss G, et al. Dietary fiber, lung function, and chronic obstructive pulmonary disease in the atherosclerosis risk in communities study. Am J Epidemiol. Mar. 1. 2008;167(5):570-8. [pmid: 18063592].
Kao WH, Folsom AR, Nieto FJ, et al. Serum and dietary magnesium and the risk for type 2 diabetes mellitus: the Atherosclerosis Risk in Communities Study. Arch Intern Med. Oct. 11. 1999;159(18):2151-9. [pmid: 10527292].
Kritchevsky SB, Tell GS, Shimakawa T, et al. Provitamin A carotenoid intake and carotid artery plaques: the Atherosclerosis Risk in Communities Study. Am J Clin Nutr. Sep. 1998;68(3):726-33. [pmid: 9734754].
Larsson SC, Bergkvist L, Näslund I, et al. Vitamin A, retinol and carotenoids and risk of gastric cancer: a prospective cohort study. Am J Clin Nutr. 2007;85:497-503. [pmid: 17284749].
Larsson SC, Giovanucci E, Wolk A. Methionine and vitamin B6 intake and risk of pancreatic cancer: a prospective study of Swedish women and men. Gastroenterology. 2007;132:113-8. [pmid: 17241865].
Larsson SC, Håkansson N, Giovannucci E, et al. Folate Intake and Pancreatic Cancer Incidence: A Prospective Study of Swedish Women and Men. J Natl Cancer Inst. 2006;98:407-13. [pmid: 16537833].
Liao F, Folsom AR, Brancati FL. Is low magnesium concentration a risk factor for coronary heart disease? The Atherosclerosis Risk in Communities (ARIC) Study. Am Heart J. Sep. 1998;136(3):480-90. [pmid: 9736141].
Ma J, Folsom AR, Melnick SL, et al. Associations of serum and dietary magnesium with cardiovascular disease, hypertension, diabetes, insulin, and carotid arterial wall thickness: the ARIC study. Atherosclerosis Risk in Communities Study. J Clin Epidemiol. Jul. 1995;48(7):927-40. [pmid: 7782801].
Millen AE, Klein R, Folsom AR, et al. Relation between intake of vitamins C and E and risk of diabetic retinopathy in the Atherosclerosis Risk in Communities Study. Am J Clin Nutr. May. 2004;79(5):865-73. [pmid: 15113727].
Peacock JM, Folsom AR, Arnett DK, et al. Relationship of serum and dietary magnesium to incident hypertension: the Atherosclerosis Risk in Communities (ARIC) Study. Ann Epidemiol. Apr. 1999;9(3):159-65. [pmid: 10192647].
Stevens J, Ahn K, Juhaeri, et al. Dietary fiber intake and glycemic index and incidence of diabetes in African-American and white adults: the ARIC study. Diabetes Care. Oct. 2002;25(10):1715-21. [pmid: 12351467].

## Women’s Antioxidant Cardiovascular Study

Albert CM, Cook NR, Gaziano JM, et al. Effect of folic acid and B vitamins on risk of cardiovascular events and total mortality among women at high risk for cardiovascular disease: a randomized trial. JAMA. May. 7. 2008;299(17):2027-36. [pmid: 18460663].
Cook NR, Albert CM, Gaziano JM, et al. A randomized factorial trial of vitamins C and E and beta carotene in the secondary prevention of cardiovascular events in women: results from the Women’s Antioxidant Cardiovascular Study. Arch Intern Med. Aug. 13–27. 2007;167(15):1610-8. [pmid: 17698683].
Song Y, Cook NR, Albert CM, et al. Effects of vitamins C and E and beta-carotene on the risk of type 2 diabetes in women at high risk of cardiovascular disease: a randomized controlled trial. Am J Clin Nutr. Aug. 2009;90(2):429-37. Epub 2009 Jun 2. [pmid: 19491386].
Zhang SM, Cook NR, Albert CM, et al. Effect of combined folic acid, vitamin B6, and vitamin B12 on cancer risk in women: a randomized trial. JAMA. Nov. 5. 2008;300(17):2012-21. [pmid: 18984888].

## Northern Swedish Health and Diseases Study

Bingham SA, Day NE, Luben R, et al. Dietary fibre in food and protection against colorectal cancer in the European Prospective Investigation into Cancer and Nutrition (EPIC): an observational study. Lancet. May. 2003;361:1496-501. [pmid: 12737858].

## Black Women’s Health Study

Van Dam RM, Hu FB, Rosenberg L, et al. Dietary calcium and magnesium, major food sources, and risk of type-2 diabetes in U.S. black women. Diabetes Care. 2006;29(10):2238-43. [pmid: 17003299].