# Materials and Methods

## Selection of the Concordant and the Discordant Example

For proof of concept, we decided to study the evidence base for two nutrient associations of disease outcomes. After feedback from a technical expert panel comprising four nutritional epidemiology and methodology experts, we selected two nutritional associations with cardiovascular mortality: one in which the results of RCTs and prospective cohorts (“observational studies”) were statistically significant and had the same direction (“concordant” example); and one in which the summary of observational studies showed a statistically significant effect, but that of the RCTs excluded any clinically important effect (“discordant” example). We chose a hard clinical outcome because such outcomes have high potential impact on public health and strongly influence clinical practice guidelines.

For the “concordant” example, we selected the relationship between the very long chain n-3 polyunsaturated fatty acids (n-3 PUFA), eicosapentaenoic acid (EPA) and docosahexaenoic acid (DHA) and cardiovascular mortality. Based on systematic reviews and meta-analyses from our team 12, 13 and others14, 15, both observational studies and RCTs associated higher EPA and DHA intake with lower cardiovascular mortality. For the “discordant” example, we selected the relationship between vitamin E intake and cardiovascular disease mortality. A meta-analysis of observational studies suggested a statistically significant association with decreased risk of coronary heart disease16, while a meta-analysis of large RCTs excluded any clinically important effect17.

For each topic we performed de novo systematic reviews and meta-analyses of RCTs and observational studies in order to become familiar with the literature and verify characterizations of “concordance” or “discordance.” We searched PubMed to identify eligible reports of RCTs and observational studies, screened them for eligibility according to predefined criteria, extracted data, and performed meta-analyses. Details are of the systematic review methodology, the characteristics of the eligible studies, and the results of the quantitative synthesis are provided in Appendix A.

## Identifying the Evidence Base in the Two Examples

The search strategies included keywords related to the nutrients of interest (n-3 PUFA or vitamin E), cardiovascular disease, and to study design terms related to observational studies or RCTs (see Appendix A for the search strategies). Searches were conducted during June and July 2010 and were limited to English-language publications. We considered that the set of publications identified in PubMed contain an adequate representation of the corresponding clinical evidence base. We also assumed this evidence base would include influential articles along major translational paths.

## Construction of Citation Networks

We then constructed the citation networks of the RCTs and observational studies included in our systematic reviews (“index” articles), and represented them as citation graphs. Appendix B provides details for how we formed the citation graphs and how we verified that they possess and fulfill theoretically anticipated properties and constraints. Briefly, among the set of articles returned by the PubMed searches, we identified those cited by the index studies directly or following citation links through one or more intermediary papers using the Thompson ISI database.

A citation graph describes citation relationships between articles in the evidence base (Figure 2). Articles are represented by vertices and citation relationships by arcs that connect pairs of vertices. The direction of each arc is from the cited toward the citing article (following the flow of information). Representing citation relationships as graphs allows us to use tools from graph theory and network analysis 18–21to characterize the evidence base and the apparent information flow in it. Without loss of clarity, we use the terms “citation network” and “citation graph” interchangeably.

Figure 2 Example of a citation network of six articles

The figure shows a citation network (represented as a citation graph) in a hypothetical evidence base of 6 articles. Each article is depicted by a vertex (A through F). The horizontal placement of the articles corresponds to their year of publication; their vertical arrangement is arbitrary–its main purpose is clarity of presentation. Arcs denote citation relationships. The direction of the arc indicates flow of information from the cited paper (beginning of the arc) to the citing paper (end of the arc). In the figure, five out of six papers (papers B through F) are connected with citation arcs. There are 4 observed citation arcs (B→D, C→D, C→E, and D→F) out of a total of 145 possible ones (from any earlier - to any subsequently published article). The density of the citation relationships is defined as the ratio of observed to possible citation arcs, i.e., here it is 4/154=0.27. Citation graphs have characteristics and properties that are described in Appendix B. Briefly, citation arcs are simple directed acyclic graphs: (1) An article does not cite itself, and there is at most one citation relationship between two articles (simple graph); (2) if one follows the direction of the citation arcs along any possible path, one cannot visit the same article twice, i.e., there are no circular directed paths (directed acyclic graph). (3) In addition, there is a temporal consistency constraint, e.g., an earlier-published article cannot cite a later-published article.

The figure shows a citation network (represented as a citation graph) in a hypothetical evidence base of 6 articles. Each article is depicted by a vertex (A through F). The horizontal placement of the articles corresponds to their year of publication; their vertical arrangement is arbitrary – its main purpose is clarity of presentation. Arcs denote citation relationships. The direction of the arc indicates flow of information from the cited paper (beginning of the arc) to the citing paper (end of the arc). In the figure, 5 out of 6 papers (papers B through F) are connected with citation arcs. There are 4 observed citation arcs (B→D, C→D, C→E, and D→F) out of a total of 15 possible ones (from any earlier- to any subsequently-published article).

## Size and Connectivity of Citation Networks

The citation networks generated are treated as operational representations of the clinical evidence base for n-3 PUFA and vitamin E. A limited evidence base (in terms of number of articles or number of citation connections between them) may indicate inconsistencies in the findings of several studies, and thus may be encountered in topics where RCTs and observational studies disagree. Reciprocally, fields where there is general congruence in the study findings may have many articles and numerous citation connections.

### Articles in the Citation Network That Report Primary Data in Humans (Pertinent Articles)

In the past we have encountered topics where there are more reviews and commentaries than papers with primary data22–25. It is therefore important to limit the analysis of citation relationships to the subset of articles that report primary data in humans. To this end, we reviewed the abstracts of the articles in the citation networks and recorded whether the article included primary data in humans (yes, no). We also recorded whether there was a clear statement describing the “intervention” or “exposure” as the nutrient of interest, and whether any clinical cardiovascular outcomes were reported. Articles containing primary data in humans and describing the exposure and the outcomes of interest were deemed “pertinent” to the association. Examples of nonpertinent articles are methodology articles, and those referring to different nutrients (e.g., alpha-linolenic acid instead of EPA or DHA for n-3 PUFA or antioxidants in general rather than vitamin E), or endpoints other than clinical cardiovascular outcomes (e.g., depression, diabetes, hypertension, lipid profiles).

### Quantification of Citation Network Size and Connectivity

Both for the initial citation networks and those limited to pertinent studies, we counted the total number of articles and the total number of citation relationships between articles in the network. These were only a subset of the total counts of citations received by an article. For example, the study on vitamin E and coronary heart disease in men by Rimm et al.26 received 101 citations within the network but has received over 1,582 citations total. We also recorded the number of citations made and number of citations received by each article (calculating the density of the citation relationships as per Figure 2), as well as the articles’ hub and authority scores. These quantify an article’s importance in the citation network. The hub score is higher for articles that cite many other articles (“integrate more information”), which were in turn connected to other articles that make many citations. The authority score is higher for articles that receive many citations and are also connected to other articles that receive many citations. These metrics convey information on the connectivity of the graph and the relative importance of articles in a network. We compared them across the n-3 PUFA and vitamin E examples using quantile–quantile (QQ) plots and Mann-Whitney tests. We used chi-squared tests for discrete characteristics.

### Relative Timing Between RCTs and Observational Studies

We collected the enrollment periods of the RCTs included in the systematic reviews and examined whether they preceded the year of publication of the observational studies. It is likely that most RCTs are conceived and designed at least a year before randomizing the first patient. Therefore the start of the enrollment period is a conservative proxy of the time when the RCT was conceived. When enrollment periods were not reported, we examined other publications of the same RCT (if available). If no data were found, we imputed the start of the enrollment period as (year of publication minus followup duration minus 1 year) and its end as (year of publication minus 1 year).

### Characterizing Information Flow in the Main Path of the Citation Networks

Main path articles integrate maximal information from previous articles and propagate information to other articles18, 19, 27, 28. They represent the most important stream of propagation of information in a citation network 18, 19, 29. By representing “major” citation relationships between key articles, the main path can provide an abstraction of the type of information that flows in a citation network. We calculated the main path of each citation network using an iterative algorithm27, 28, and reviewed the full text of its articles. Examples of articles that are likely to be selected in the main path are major RCTs or major observational studies (including seminal articles) because they are often cited as key articles; and systematic reviews and meta-analyses, because they make references to relevant articles, and because they are often cited by subsequently published articles as state-of-the-science summaries.