# Appendix References

1 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. September. 1986;7(3):177-88. [pmid: 3802833].
2 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. June. 15. 2002;21(11):1539-58. [pmid: 12111919].
3 Hamling J, Lee P, Weitkunat R, et al. Facilitating meta-analyses by deriving relative effect and precision estimates for alternative comparisons from a set of estimates presented by exposure level or disease category. Stat Med. March. 30. 2008;27(7):954-70. [pmid: 17676579].
4 Mozaffarian D, Rimm EB. Fish intake, contaminants, and human health: evaluating the risks and the benefits. JAMA. October. 18. 2006;296(15):1885-99. [pmid: 17047219].
5 Kris-Etherton PM, Harris WS, Appel LJ. Fish consumption, fish oil, omega-3 fatty acids, and cardiovascular disease. Circulation. November. 19. 2002;106(21):2747-57. [pmid: 12438303].
6 Wallace BC, Schmid CH, Lau J, et al. Meta-Analyst: software for meta-analysis of binary, continuous and diagnostic data. BMC Med Res Methodol. 2009;9:80. [pmid: 19961608].
7 Durrington PN, Bhatnagar D, Mackness MI, et al. An omega-3 polyunsaturated fatty acid concentrate administered for one year decreased triglycerides in simvastatin treated patients with coronary heart disease and persisting hypertriglyceridaemia. Heart. May. 2001;85(5):544-8. [pmid: 11303007].
8 Calo L, Bianconi L, Colivicchi F, et al. N-3 Fatty acids for the prevention of atrial fibrillation after coronary artery bypass surgery: a randomized, controlled trial. J Am Coll Cardiol. May. 17. 2005;45(10):1723-8. [pmid: 15893193].
9 Marchioli R, Levantesi G, Macchia A, et al. Antiarrhythmic mechanisms of n-3 PUFA and the results of the GISSI-Prevenzione trial. J Membr Biol. July. 2005;206(2):117-28. [pmid: 16456722].
10 Macchia A, Levantesi G, Franzosi MG, et al. Left ventricular systolic dysfunction, total mortality, and sudden death in patients with myocardial infarction treated with n-3 polyunsaturated fatty acids. Eur J Heart Fail. August. 2005;7(5):904-9. [pmid: 16087142].
11 Nilsen DW, Albrektsen G, Landmark K, et al. Effects of a high-dose concentrate of n-3 fatty acids or corn oil introduced early after an acute myocardial infarction on serum triacylglycerol and HDL cholesterol. Am J Clin Nutr. July. 2001;74(1):50-6. [pmid: 11451717].
12 Sacks FM, Stone PH, Gibson CM, et al. Controlled trial of fish oil for regression of human coronary atherosclerosis. HARP Research Group. J Am Coll Cardiol. June. 1995;25(7):1492-8.
13 Singh RB, Niaz MA, Sharma JP, et al. Randomized, double-blind, placebo-controlled trial of fish oil and mustard oil in patients with suspected acute myocardial infarction: the Indian experiment of infarct survival--4. Cardiovasc Drugs Ther. July. 1997;11(3):485-91. [pmid: 9310278].
14 Tavazzi L, Maggioni AP, Marchioli R, et al. Effect of n-3 polyunsaturated fatty acids in patients with chronic heart failure (the GISSI-HF trial): a randomised, double-blind, placebo-controlled trial. Lancet. October. 4. 2008;372(9645):1223-30. [pmid: 18757090].
15 von SC, Angerer P, Kothny W, et al. The effect of dietary omega-3 fatty acids on coronary atherosclerosis. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. April. 6. 1999;130(7):554-62. [pmid: 10189324].
16 Johansen O, Seljeflot I, Hostmark AT, et al. The effect of supplementation with omega-3 fatty acids on soluble markers of endothelial function in patients with coronary heart disease. Arterioscler Thromb Vasc Biol. July. 1999;19(7):1681-6. [pmid: 10397685].
17 Leng GC, Lee AJ, Fowkes FG, et al. Randomized controlled trial of gamma-linolenic acid and eicosapentaenoic acid in peripheral arterial disease. Clin Nutr. December. 1998;17(6):265-71. [pmid: 10205349].
18 Yokoyama M, Origasa H, Matsuzaki M, et al. Effects of eicosapentaenoic acid on major coronary events in hypercholesterolaemic patients (JELIS): a randomised open-label, blinded endpoint analysis. Lancet. March. 31. 2007;369(9567):1090-8. [pmid: 17398308].
19 Brouwer IA, Zock PL, Camm AJ, et al. Effect of fish oil on ventricular tachyarrhythmia and death in patients with implantable cardioverter defibrillators: the Study on Omega-3 Fatty Acids and Ventricular Arrhythmia (SOFA) randomized trial. JAMA. June. 14. 2006;295(22):2613-9. [pmid: 16772624].
20 Leaf A, Albert CM, Josephson M, et al. Prevention of fatal arrhythmias in high-risk subjects by fish oil n-3 fatty acid intake. Circulation. November. 1. 2005;112(18):2762-8. [pmid: 16267249].
21 Raitt MH, Connor WE, Morris C, Kron, et al. Fish oil supplementation and risk of ventricular tachycardia and ventricular fibrillation in patients with implantable defibrillators: a randomized controlled trial. JAMA. June. 15. 2005;293(23):2884-91. [pmid: 15956633].
22 Yuan JM, Ross RK, Gao YT, et al. Fish and shellfish consumption in relation to death from myocardial infarction among men in Shanghai, China. Am J Epidemiol. November. 1. 2001;154(9):809-16. [pmid: 11682363].
23 Pietinen P, Ascherio A, Korhonen P, et al. Intake of fatty acids and risk of coronary heart disease in a cohort of Finnish men. The Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study. Am J Epidemiol. May. 15. 1997;145(10):876-87. [pmid: 9149659].
24 Nagata C, Takatsuka N, Shimizu H. Soy and fish oil intake and mortality in a Japanese community. Am J Epidemiol. November. 1. 2002;156(9):824-31. [pmid: 12397000].
25 Kaushik S, Wang JJ, Flood V, et al. Frequency of fish consumption, retinal microvascular signs and vascular mortality. Microcirculation. January. 2008;15(1):27-36. [pmid: 17907016].
26 Kamphuis MH, Geerlings MI, Tijhuis MA, et al. Depression and cardiovascular mortality: a role for n-3 fatty acids. Am J Clin Nutr. December. 2006;84(6):1513-7. [pmid: 17158437].
27 Jarvinen R, Knekt P, Rissanen H, et al. Intake of fish and long-chain n-3 fatty acids and the risk of coronary heart mortality in men and women. Br J Nutr. April. 2006;95(4):824-9. [pmid: 16571163].
28 Iso H, Kobayashi M, Ishihara J, et al. Intake of fish and n3 fatty acids and risk of coronary heart disease among Japanese: the Japan Public Health Center-Based (JPHC) Study Cohort I. Circulation. January. 17. 2006;113(2):195-202. [pmid: 16401768].
29 Folsom AR, Demissie Z. Fish intake, marine omega-3 fatty acids, and mortality in a cohort of postmenopausal women. Am J Epidemiol. November. 15. 2004;160(10):1005-10. [pmid: 15522857].
30 Dolecek TA. Epidemiological evidence of relationships between dietary polyunsaturated fatty acids and mortality in the multiple risk factor intervention trial. Proc Soc Exp Biol Med. June. 1992;200(2):177-82. [pmid: 1579579].
31 Albert CM, Hennekens CH, O'Donnell CJ, et al. Fish consumption and risk of sudden cardiac death. JAMA. January. 7. 1998;279(1):23-8. [pmid: 9424039].
32 Virtamo J, Rapola JM, Ripatti S, et al. Effect of vitamin E and beta carotene on the incidence of primary nonfatal myocardial infarction and fatal coronary heart disease. Arch Intern Med. March. 23. 1998;158(6):668-75. [pmid: 9521232].
33 Stephens NG, Parsons A, Schofield PM, et al. Randomised controlled trial of vitamin E in patients with coronary disease: Cambridge Heart Antioxidant Study (CHAOS). Lancet. March. 23. 1996;347(9004):781-6. [pmid: 8622332].
34 Boaz M, Smetana S, Weinstein T, et al. Secondary prevention with antioxidants of cardiovascular disease in endstage renal disease (SPACE): randomised placebo-controlled trial. Lancet. October. 7. 2000;356(9237):1213-8. [pmid: 11072938].
35 Dietary supplementation with n-3 polyunsaturated fatty acids and vitamin E after myocardial infarction: results of the GISSI-Prevenzione trial. Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto miocardico. Lancet. August. 7. 1999;354(9177):447-55. [pmid: 10465168].
36 Rapola JM, Virtamo J, Ripatti S, et al. Randomised trial of alpha-tocopherol and beta-carotene supplements on incidence of major coronary events in men with previous myocardial infarction. Lancet. June. 14. 1997;349(9067):1715-20. [pmid: 9193380].
37 Sacco M, Pellegrini F, Roncaglioni MC, et al. Primary prevention of cardiovascular events with low-dose aspirin and vitamin E in type 2 diabetic patients: results of the Primary Prevention Project (PPP) trial. Diabetes Care. December. 2003;26(12):3264-72. [pmid: 14633812].
38 Lonn E, Bosch J, Yusuf S, et al. Effects of long-term vitamin E supplementation on cardiovascular events and cancer: a randomized controlled trial. JAMA. March. 16. 2005;293(11):1338-47. [pmid: 15769967].
39 Lee IM, Cook NR, Gaziano JM, et al. Vitamin E in the primary prevention of cardiovascular disease and cancer: the Women's Health Study: a randomized controlled trial. JAMA. July. 6. 2005;294(1):56-65. [pmid: 15998891].
40 Hodis HN, Mack WJ, LaBree L, et al. Alpha-tocopherol supplementation in healthy individuals reduces low-density lipoprotein oxidation but not atherosclerosis: the Vitamin E Atherosclerosis Prevention Study (VEAPS). Circulation. September. 17. 2002;106(12):1453-9. [pmid: 12234947].
41 de GG. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Collaborative Group of the Primary Prevention Project. Lancet. January. 13. 2001;357(9250):89-95. [pmid: 11197445].
42 Cook NR, Albert CM, Gaziano JM, et al. A randomized factorial trial of vitamins C and E and beta carotene in the secondary prevention of cardiovascular events in women: results from the Women's Antioxidant Cardiovascular Study. Arch Intern Med. August. 13. 2007;167(15):1610-8. [pmid: 17698683].
43 Devaraj S, Tang R, ms-Huet B, et al. Effect of high-dose alpha-tocopherol supplementation on biomarkers of oxidative stress and inflammation and carotid atherosclerosis in patients with coronary artery disease. Am J Clin Nutr. November. 2007;86(5):1392-8. [pmid: 17991651].
44 Milman U, Blum S, Shapira C, et al. Vitamin E supplementation reduces cardiovascular events in a subgroup of middle-aged individuals with both type 2 diabetes mellitus and the haptoglobin 2-2 genotype: a prospective double-blinded clinical trial. Arterioscler Thromb Vasc Biol. February. 2008;28(2):341-7. [pmid: 18032779].
45 Sesso HD, Buring JE, Christen WG, et al. Vitamins E and C in the prevention of cardiovascular disease in men: the Physicians' Health Study II randomized controlled trial. JAMA. November. 12. 2008;300(18):2123-33. [pmid: 18997197].
46 Fraser GE, Shavlik DJ. Risk factors for all-cause and coronary heart disease mortality in the oldest-old. The Adventist Health Study Arch Intern Med. October. 27. 1997;157(19):2249-58.
47 Losonczy KG, Harris TB, Havlik RJ. Vitamin E and vitamin C supplement use and risk of all-cause and coronary heart disease mortality in older persons: the Established Populations for Epidemiologic Studies of the Elderly. Am J Clin Nutr. August. 1996;64(2):190-6. [pmid: 8694019].
48 Knekt P, Reunanen A, Jarvinen R, et al. Antioxidant vitamin intake and coronary mortality in a longitudinal population study. Am J Epidemiol. June. 15. 1994;139(12):1180-9. [pmid: 8209876].
49 Kushi LH, Folsom AR, Prineas RJ, et al. Dietary antioxidant vitamins and death from coronary heart disease in postmenopausal women. N Engl J Med. May. 2. 1996;334(18):1156-62. [pmid: 8602181].
50 Sahyoun NR, Jacques PF, Russell RM. Carotenoids, vitamins C and E, and mortality in an elderly population. Am J Epidemiol. September. 1. 1996;144(5):501-11. [pmid: 8781466].
51 Pocobelli G, Peters U, Kristal AR, et al. Use of supplements of multivitamins, vitamin C, and vitamin E in relation to mortality. Am J Epidemiol. August. 15. 2009;170(4):472-83. [pmid: 19596711].
52 Buijsse B, Feskens EJ, Kwape L, et al. Both alpha- and beta-carotene, but not tocopherols and vitamin C, are inversely related to 15-year cardiovascular mortality in Dutch elderly men. J Nutr. February. 2008;138(2):344-50. [pmid: 18203902].
53 Genkinger JM, Platz EA, Hoffman SC, et al. Fruit, vegetable, and antioxidant intake and all-cause, cancer, and cardiovascular disease mortality in a community-dwelling population in Washington County, Maryland. Am J Epidemiol. December. 15. 2004;160(12):1223-33. [pmid: 15583375].
54 Dietrich M, Jacques PF, Pencina MJ, et al. Vitamin E supplement use and the incidence of cardiovascular disease and all-cause mortality in the Framingham Heart Study: Does the underlying health status play a role. Atherosclerosis. August. 2009;205(2):549-53. [pmid: 19195657].
55 Iso H, Kubota Y. Nutrition and disease in the Japan Collaborative Cohort Study for Evaluation of Cancer (JACC). Asian Pac J Cancer Prev. 2007;8(Suppl):35-80. [pmid: 18260705].
56 Todd S, Woodward M, Tunstall-Pedoe H, et al. Dietary antioxidant vitamins and fiber in the etiology of cardiovascular disease and all-causes mortality: results from the Scottish Heart Health Study. Am J Epidemiol. November. 15. 1999;150(10):1073-80. [pmid: 10568622].
57 Klipstein-Grobusch K, Geleijnse JM, den Breeijen JH, et al. Dietary antioxidants and risk of myocardial infarction in the elderly: the Rotterdam Study. Am J Clin Nutr. February. 1999;69(2):261-6. [pmid: 9989690].
58 Rimm EB, Stampfer MJ, Ascherio A, et al. Vitamin E consumption and the risk of coronary heart disease in men. N Engl J Med. May. 20. 1993;328(20):1450-6. [pmid: 8479464].
59 Stampfer MJ, Hennekens CH, Manson JE, et al. Vitamin E consumption and the risk of coronary disease in women. N Engl J Med. May. 20. 1993;328(20):1444-9. [pmid: 8479463].
60 Batagelj V. Efficient algorithms for citation network analysis. Preprint series. 2003;41(897). University of Ljubljana, Institute of Mathematics, Physics, and Mechanics, Department of Theoretical Computer Science www.imfm.si/preprinti/PDF/00897.pdf.
61 Hummon N, Doreian P. Connectivity in a citation network: the development of DNA theory. Social Networks. 1989;11:39-63.
62 Hummon N, Doreian P. Computational methods for social network analysis. Social Networks. 1990;12:273-88.
63 Harris JK, Luke DA, Zuckerman RB, et al. Forty years of secondhand smoke research: the gap between discovery and delivery. Am J Prev Med. June. 2009;36(6):538-48. [pmid: 19372026].
64 de Nooy W, Mrvar A, Batagelj V. Exploratory social network analysis with Pajek. Granovetter M, editor. Structural analysis in the social sciences. New York. Cambridge University Press. 2005.