# Meta-analysis Methodology

As described in the main text, we examined the citation networks of a “concordant” and a “discordant” example. Based on feedback from four nutrition and methodology experts we selected the relationship between omega-3 fatty acids, namely eicosapentaenoic acid (EPA) and docosahexaenoic acid (DHA), with cardiovascular mortality for the “concordant” example and the relationship between vitamin E intake and cardiovascular disease mortality for the “discordant” example.

For each topic, we first updated and reanalyzed the meta-analyses of randomized trials and observational studies in order to become familiar with the literature and verify characterizations of “concordance” or “discordance” between the summary findings of randomized trials and observational studies. The following outlines the methodology used.

## Literature Searches

The following search strategies were used.

### Omega-3 Fatty Acids and Cardiovascular Mortality Example

(((“dietary fats, unsaturated” [MeSH Terms] OR “fish oils” [MeSH Terms] OR “omega 3” [Text Word] OR “linolenic” [Text Word] OR “docosahexaenoic” [Text Word] OR “eicosapentaenoic” [Text Word] OR “Fish oil” [Text Word] OR “Fatty acids” [Text Word] OR “Fish consumption” [Text Word] OR “omega3” [Text Word]) AND (cardiovascular disease OR mortality)) AND (cohort OR prospective trial OR clinical trial OR controlled trial OR longitudinal study OR prospective study OR randomised OR randomized OR Prevenzione)).

Note that the list of keywords also includes specific terms to also capture studies that are otherwise missed by the search. The last search was performed on 06/15/2010 and returned 2,741 citations. Without limiting the eligible study designs, the number of returned articles was well above 14,000, a number deemed too large for the intended analyses.

### Vitamin E and Cardiovascular Mortality Example

((((((((((cardiovascular disease) OR coronary heart disease) OR hypertension) OR blood pressure) OR heart failure) OR ischaemia) OR Japan[Title] OR Collaborative[Title]) OR cardiovascular events[Title]) OR “myocardial infarction”[MeSH Terms]) OR mortality[MeSH Terms]) AND (((((((Vitamin E) OR Vitamin C and E) OR “tocopherol”[All Fields]) OR “alpha tocopherol”[All Fields]) OR “antioxidant”[All Fields]) OR supplementation) OR Adventist[Title]) AND ((((((("randomized controlled trials as topic"[MeSH Terms]) OR “cohort studies”[MeSH Terms]) OR “prospective studies”[MeSH Major Topic]) OR “epidemiologic”[All Fields]) OR “study”[Title]) OR trial[Title]) OR incidence[Title]).

Note that the list of keywords also includes specific terms to also capture studies that are otherwise missed by the search. The last search was performed on 07/10/2010 and returned 2,825 articles. The search returned well over 22,000 citations without the terms for study designs.

## Eligibility Criteria

Based on input from the technical expert panel, we formed the following eligibility criteria for randomized trials or observational studies in the two examples. Two methodologists evaluated potentially relevant articles that met eligibility criteria. Any disagreements were resolved by consensus, or by a third arbitrator when consensus could not be reached.

### Omega-3 Fatty Acids and Cardiovascular Mortality Example

We included randomized controlled trials (irrespective of size or duration) and prospective cohorts (with at least 3 years of followup and at least 1,000 participants) reporting on the association between EPA or DHA intake and cardiac or all-cause mortality. For RCTs, the interventions of interest were EPA, DHA, or fish oil (defining fish oils as EPA and DHA). For the prospective cohorts, our exposure of interest was dietary intake levels of long chain n-3 fatty acids, either as fish or fish oil supplements. Studies containing information on fish intake without reporting amount of EPA and DHA or interventions that involved alpha-linoleic acid (ALA) only were excluded. Eligible were studies on human subjects with or without a history of cardiovascular disease (secondary or primary prevention settings, respectively). Two methodologists evaluated potentially relevant articles that met eligibility criteria. Any disagreements were resolved by consensus, or by a third arbitrator when consensus could not be reached.

### Vitamin E and Cardiovascular Mortality Example

We included randomized controlled trials (irrespective of size or duration) and prospective cohorts (with at least 3 years of followup and at least 500 participants) reporting on the association between vitamin E intake and cardiac or all-cause mortality. For RCTs, the interventions of interest were vitamin E intake, most commonly through supplementation. Studies including multivitamin supplementation were not considered. For the prospective cohorts, our exposure of interest was dietary intake levels of vitamin E, or total vitamin E intake including dietary and supplement sources. Eligible were studies on human subjects with or without a history of cardiovascular disease (secondary or primary prevention settings, respectively).

## Data Extraction

Data extraction included the following items: study design, population characteristics (country, demographics), type and intake or dosage of nutrient (EPA and DHA or vitamin E), comparison groups (placebo or comparative control, when applicable), sample size, and outcomes of interest. We accepted the definition of cardiac or cardiovascular death that was used in the primary studies. Typically, this was deaths ascribed to coronary heart disease or sudden death.

For randomized trials, we extracted number of events in the intervention and control groups. For prospective cohorts we recorded risk or hazard ratios for each quantile-category (i.e., tertiles, quartiles, or quintiles) of estimates of nutrient intake (EPA and DHA or vitamin E) compared with a reference group. We also classified the adjustments performed in each prospective cohort into eight categories: (1) demographic (i.e., age, marital status, race, gender, area); (2) socioeconomic (i.e., education, occupation); (3) anthropometric (i.e., body mass index); (4) health (i.e., CVD, history of hypertension, diabetes, hypercholesterolemia, or blood pressure); (5) lifestyle (i.e., smoking, alcohol consumption); (6) nutrients (i.e., dietary intakes of cholesterol, saturated fat, omega-6 polyunsaturated fatty acids); (7) energy (i.e., total energy intake), and other factors (i.e., treatment assignment). When several alternative analyses were reported, we preferred the one that adjusted at least for demographic and anthropometric predictors, health and energy.

## Evidence Synthesis for Randomized Trials

We calculated summary risk ratios by random effects meta-analysis using the DerSimonian and Laird model. 1We tested for between-study heterogeneity with the Q statistic (considered significant at the 0.10 level) and quantified its extent with the I^2^ statistic.2I^2^ ranges between 0 and 100 percent and expresses the proportion of between study variance that is attributable to heterogeneity rather than chance.

## Evidence Synthesis for Prospective Cohorts

Prospective cohort studies typically perform categorical analyses for nutrient intake. When adequate statistics are reported, one can perform dose-response analyses, i.e., explore the presence or absence of an association between higher average nutrient intake and risk for cardiovascular disease. Such analyses were possible in the omega-3 and cardiovascular mortality example, but not in the vitamin E example, in which simpler analyses were performed (see below). For this reason, the actual meta-analyses in the two examples follow different methodologies.

### Omega-3 and Cardiovascular Mortality Example

Details on the analyses of this example are described in a different manuscript. Briefly, we back-calculated the “effective counts” of events in each category of EPA and DHA intake based on the reported adjusted log odds ratios (versus a reference intake category), their variance, and the total number of participants per intake category and solving a set of nonlinear equations.3 The effective counts of events are such that when used in a logistic regression with the intake categories as the sole predictors they result in the same log odds ratios (coefficients) variances and covariances as those from the original adjusted model. If one started from the results of an unadjusted model, the effective counts would be identical to the actual event counts.

We then evaluated the association between cardiac or all-cause mortality and mean intake levels across all studies in meta-regression models using the exact binomial likelihood. We report results from a fixed-intercept–random slope model (a mixed effects meta-regression), which explicitly models between-study variability in the strength of the dose-response relationship, and is the analogue of a random effects meta-analysis. The meta-regression model that allowed different associations for mean intake levels above or below 0.20 grams per day (using a piecewise linear spline with a knot at the corresponding threshold). This analysis explicitly addresses the claim that the effects of EPA and DHA plateau at a low intake value (0.20 to 0.25 grams per day).4 The above threshold are in the same range as the currently recommended intake of EPA and DHA per day.5

### Vitamin E and Cardiovascular Mortality Example

As mentioned above, prospective cohorts in the vitamin E example did not report sufficient statistics to perform analogous dose-response analyses. Therefore, we performed random effect meta-analyses 1of the hazard ratios of various intake categories (the lowest intake category being the reference) across all intake categories of all studies. This approach is problematic in that it ignores the mean intake of vitamin E in the various categories; and ignores the fact that hazard ratios for intake categories obtained from the same study are correlated (they are all obtained versus a common reference). Therefore the summary effect is not easily translated, and should be viewed as a measurement of association between the nutrient and the risk of death. We considered this analysis acceptable for the purpose of this paper, as it is used only to show that the summary results from observational studies are very different than those from the randomized trials.

## Software

Analyses were performed in Stata (flavor SE, version 11, Stata Corporation, College Station, Texas) and Meta-Analyst (version 3 beta, Boston).6 Unless otherwise stated, all tests are two-tailed and considered significant when p<0.05.

## Meta-analysis Results

### Omega-3 Fatty Acids and Cardiovascular Mortality – Randomized Trials

Table A1 summarizes characteristics of the 14 eligible randomized trials (reported in 15 publications).7-21 They enrolled patients with a history of heart disease, risk factors for heart disease. The majority included predominantly male patients with mean ages in the early 60s. Daily supplement doses ranged from approximately 0.30 to 6 grams. Control arms received a variety of non-marine oils (Table A1). The 15 publications 7-21 constituted the index randomized trials in the main citation analysis.

Table A1 Randomized controlled trials of the effects of omega-3 fatty acid supplements

Study (Year), Country | Mean age [y] (Males [%]) | Population | Intervention | | | Control
Study (Year), Country | Mean age [y] (Males [%]) | Population | N | Description | | N | | Description
Trials reporting analyzable data on cardiovascular mortality
Sacks (1995), US12 | 62 (93) | CAD | 31 | EPA+DHA | | 28 | | Non-marine oil
Johansen (1999), Norway16 | 60 (78) | CAD patients undergoing PTCA | 250 | EPA+DHA | | 250 | | Placebo
Durrington (2001), United Kingdom7 | 59 (73) | CHD | 30 | EPA +DHA + simvastatin | | 29 | | Non-marine oil + simvastatin
Nilsen (2001), Norway11 | 64 (80) | Recent MI | 150 | EPA+DHA | | 150 | | Non-marine oil
GISSI-Prevenzione (2002), Italy 9;10 | 60 (85) | Recent MI | 5665 | EPA+DHA ± vitamin E | | 5658 | | No EPA/DHA supplement ± vitamin E
GISSI-HF (2008), Italy14 | 67 (78) | Heart failure | 3494 | EPA+DHA | | 3481 | | Placebo
Yokoyama (2007), Japan18 | 61 (32) | Hypercholester olemia | 9326 | EPA + statins | | 9319 | | Statins
Brouwer (2006), Europe^*^ 19 | 62 (84) | Patients with ICD | 273 | Fish oil | | 273 | | Non-marine oil
Leaf (2005), US20 | 66 (83) | Patients with ICD | 200 | EPA+DHA | | 202 | | Non-marine oil
Raitt (2005), US21 | 63 (86) | Patients with ICD | 100 | EPA+DHA | | 100 | | Non-marine oil
Trials that do not report analyzable data on cardiovascular mortality, but report data on all-cause mortality
von Schacky (1999), Germany15 | 59 (76) | CAD | 111 | EPA+DHA | 112 | | Non-marine oil
Calo (2005), Italy8 | 66 (85) | Patients undergoing CABG | 79 | EPA+DHA | 81 | | Placebo
Singh (1997), India13 | 49 (93) | Recent MI | 122 | EPA+DHA | 118 | | Aluminum hydroxide
Leng (1998), Scotland17 | 66 (68) | Claudication | 60 | EPA | 60 | | Non-marine oil

EPA = eicosapentaenoic acid; CAD = coronary artery disease; CHD = coronary heart disease; DHA = docosahexaenoic acid; ICD = implantable cardioverter defibrillators; MI = myocardial infarction; GISSI-HF or –Prevenzione = Gruppo Italiano per lo Studio della Sopravvivenza nell’Infarto miocardico –Heart Failure or –Prevenzione

* Poland, Germany, the Netherlands, United Kingdom, Czech Republic, Belgium, Austria, Switzerland

Of these, 10 (39,249 patients)7;9-12;14;16;18-21 were included in the meta-analysis of relative risks for cardiovascular mortality – the rest reported only all cause mortality outcomes. The random effects summary relative risk was 0.88 (95% CI, 0.82, 0.95), with no evidence for heterogeneity. In sensitivity analyses we repeated the whole citation analysis using only the 10 meta-analyzed trials as index randomized trials.

### Omega-3 Fatty Acids and Cardiovascular Mortality – Observational Studies

Table A2 summarized the 10 prospective cohorts that fulfilled eligibility criteria. Studies included participants without prior history of cardiovascular disease.22-31 EPA and DHA intake was estimated from fish consumption using frequency questionnaires in six studies and dietary history questionnaires in two studies. All except one study26 reported using a validated method to assess EPA and DHA intake and survival status, and performed multivariate analyses adjusting for potential confounders. The 10 publications22-31 constituted the index observational studies in the main citation analysis.

Table A2 Prospective cohort studies on the effects of omega-3 fatty acid consumption on cardiovascular or all-cause mortality in the general population

Author, Year, Country (Ref) | Sample Size | | | Males (%) | | Age Mean (range), [y] | | Dietary Assessment | | n-3 Fatty Acid Intake (g/d)^*^ | | Duration (y)
Studies reporting analyzable data on cardiovascular mortality outcomes
Pietinen et al, 1997, Finland23 | 21,930 | | | 100 | | ND (50-69) | | FFQ | | 0.4 | | 6.1
Yuan et al, 2001, China22 | 18,244 | | | 100 | | 56 (45-64) | | FFQ | | 0.1 | | 12
Jarvinen et al, 2006, Finland27 | 5,220 | | | (data reported per sex) | | 45 (30-79) | | Dietary history method | | 0.3 (men) 0.2 (women) | | 21.5
Kamphuis et al, 2006, Netherlands26 | 2,574 | | | 100 | | ND (70-90) | | Dietary history method | | 0.1 | | 10
Iso et al, 2006, Japan28 | 33,262 | | | 48 | | ND (40-59) | | FFQ | | 0.9 | | 10
Albert et al, 1998, US31 | 20,551 | | | 100 | | ND (40-84) | | FFQ | | 0.3 | | 11
Studies that do not report analyzable data on cardiovascular mortality, but report data on all-cause mortality and cardiovascular clinical outcomes
Folsom et al. 2004, US29 | | 41,835 | 0 | | 54 (55-69) | | FFQ | | 0.1 | | 14
Nagata et al, 2002, Japan24 | | 29,080 | 46 | | 55 (35-ND) | | FFQ | | 0.8 | | 7
Dolecek et al., 1992, US30 | | 6,250 | 100 | | (35-57) | | Multiple 24-hr dietary recall | | 0.04 | | 10.5
Kaushik et al, 2008, Australia25 | | 2,683 | 56 | | 49 | | FFQ | | ND | | 10

FFQ = food frequency questionnaire; ND = no data

Six studies22;23;26-28;31 reported sufficient statistics to be included in the mixed-effects dose-response meta-regression analyses for the association between EPA and DHA and cardiac, cardiovascular or sudden death (corresponding to 7 meta-analysis entries as Jarvinen et al.27 reported separate data per sex). In the dose-response meta-regressions, higher mean EPA and DHA intake up to 0.20 grams daily was associated with decreased risk of cardiac, cardiovascular or sudden death (odds ratio 0.62 per 0.20 grams average daily intake, 95% CI: 0.45 to 0.86 –data on 83,578 participants), with no significant change in risk at higher mean intakes.

In sensitivity analyses we repeated the whole citation analysis using only the 6 meta-analyzed studies as index observational studies.

### Vitamin E and Cardiovascular Mortality – Randomized Trials

Table A3 summarizes characteristics of the 14 eligible randomized trials (111,481 patients).32-45 They enrolled patients with a history of heart disease, risk factors for heart disease. The majority included predominantly male patients with mean ages in the early sixties. Daily supplement doses ranged from approximately 50 to 1,200 international units (IU) per day; 12 of the 14 trials used doses between 300 and 800 IU per day. These 14 publications 32-45 constituted the index randomized trials in the main citation analysis.

Table A3 Characteristics of randomized trials of vitamin E supplements

Study (Year), Country | Mean age [y] (Males [%]) | Population | Intervention | | Control
Study (Year), Country | Mean age [y] (Males [%]) | Population | N | Description | N | Description
Stephens (1996), UK33 | 62 (84) | Coronary atherosclerosis | 1,035 | Vit E | 967 | Placebo
Rapola (1997) Finland36 | 59 (100) | Prior MI | 466 | Vit E | 438 | Placebo
Virtamo (1998), Finland32 | 57 (100) | CVD risk factors, no prior MI | 6,820 | Vit E | 6,849 | Placebo and/or vit A
GISSI-P (1999), Italy35 | 60 (85) | Prior MI | 5,660 | Vit E | 5,664 | Placebo
Boaz (2000), Israel34 | 69 (69) | CVD patients on dialysis | 97 | Vit E | 99 | Placebo
de Gaetano (2001), Italy41 | 64 (42) | CVD risk factors | 2,231 | Vit E | 2,264 | No supplement
Hodis (2002), US40 | 56 (49) | General population | 177 | Vit E | 176 | Placebo
Sacco (2003), Italy37 | 64 (43) | CVD risk factors | 1,877 (no DM), 509 (DM) | Vit E | 1,877 (no DM), 522 (DM) | No supplement
Lee (2005), US39 | 55 (0) | General population | 19,937 | Vit E | 19,939 | Placebo
Lonn (2005), Canada38 | 66 (74) | History of CVD | 4,761 | Vit E | 4,780 | Placebo
Cook (2007), US42 | 61 (0) | History of CVD | 4,083 | Vit E | 4,088 | [Not stated]
Devaraj (2007), US43 | 61 (72) | History of CAD | 44 | Vit E | 46 | Soybean oil
Milman (2008), Israel44 | 69 (48) | Type 2 DM | 726 | Vit E | 708 | Placebo
Sesso (2008), US45 | 64 (100) | With or without history of CVD | 7,315 | Vit E | 7,326 | Placebo and/or vit C

CVD = cardiovascular disease; DM = diabetes mellitus; GISSI-P = Gruppo Italiano per lo Studio della Sopravvivenza nell’Infarto miocardico –Prevenzione; MI = myocardial infarction; vit = vitamin

* This is a subset of participants relevant to our comparison of interest

All 14 randomized trials were included in the meta-analysis. The summary risk ratio was 0.97 (95% confidence interval, CI: 0.91, 1.03), with no evidence for heterogeneity. In the sensitivity analyses of the citation networks, the index randomized trials for the vitamin E example are the same as in the main citation analysis (all 14 trials were included in the meta-analysis).

### Vitamin E and Cardiovascular Mortality – Observational Studies

Table A4 summarizes the results of 14 prospective cohorts that fulfilled eligibility criteria. 46-59 Studies included participants without prior history of cardiovascular disease. Intake was estimated mainly from food frequency questionnaires. All studies performed multivariate analyses adjusting for potential confounders. The 14 publications constituted the index observational studies in the main citation analysis.46-59

Table A4 Study characteristics of prospective cohort studies of vitamin E intake in relation to cardiovascular mortality, coronary heart disease and myocardial infarction

Author (Year) Country | Sample Size | | Males (%) | | Age Mean (Range), [y] | Dietary Assessment | Duration (y)
Studies reporting analyzable data on the association of vitamin E and cardiovascular mortality
Knekt (1994) Finland 48 Finnish Mobile Clinic Study | 2,748 (male stratum); 2,385 (female stratum) | | 54 | | 50 | Other | 14
Kushi (1996) US 49 Iowa Women’s Health Study | 34,486 | | 0 | | 61 | FFQ | 7
Losonczy (1996) US 47 Established Populations for Epidemiologic Studies of the Elderly | 11,178 (9,685 relevant) | | 36.6 | | 75 (≥65) | Questionnaire on supplement use | 10
Sahyoun (1996) US 50 Boston Nutrition Status Survey | 747 | | 35 | 73 | | Diet record | 12
Fraser (1997) US 46 Adventist Health Study | 603 | | 29 | 88 | | FFQ | 12
Genkinger (2004) US 53 CLUE I and CLUE II | 6,151 | | 37 | 56.3 (30-93) | | FFQ | 15
Buijsse (2008) Netherlands 52 Zutphen Elderly Study | 1,266 | | 100 | 72 | | Cross-check dietary history method | 15
Pocobelli (2009) US 51 The Vitamins and Lifestyle Study | 77,673 | | 48 | ~60 (50-76) | | FFQ, and questionnaire on supplement use | 6
Studies that do not report analyzable data on the association of vitamin E and cardiovascular mortality but report data on associations with nonfatal cardiovascular disease outcomes
Rimm (1993) US 58 Health Professional Follow-up Study | 39,910 | 100 | | 54 | | FFQ | 4
Stampfer (1993) US 59 Nurses’ Health Study | 121,700 (87,245 relevant) | 0 | | 47 | | FFQ | 8
Klipstein-Grobusch (1999) Netherlands 57 Rotterdam Study | 7,983 (4,802 relevant) | 39 | | 68 | | Semi-quantitative FFQ | 4
Todd (1999) Scotland 56 Scottish Heart Health Study | 11,629 | 51 | | 50 | | Semi-quantitative FFQ | 7.7
Iso (2007) Japan55 Collaborative Cohort Study | 44,534 (male stratum) 60,883 (female stratum) | 42 | | ND | | FFQ | ND
Dietrich (2009) US54 Framingham Heart Study | 4,270 | 46 | | 59.5 | | FFQ | 10

FFQ = food frequency questionnaire; ND = no data

Eight studies46-53 reported sufficient statistics to be included in the random effects meta-analyses for the association between vitamin E intake and cardiovascular mortality. The remaining six only reported data on nonfatal clinical cardiovascular disease outcomes.54-59

Overall, in the eight meta-analyzed studies, vitamin E intake was associated with decreased risk of cardiovascular death (summary hazard ratio 0.85, 95% CI: 0.78 to 0.93), with little evidence of heterogeneity (I^2^=26%, p-value = 0.13). In sensitivity analyses, we repeated the citation analysis using only the eight meta-analyzed studies as index observational studies.