# Appendixes

Appendix A Meta-analysis Methodology

Appendix B Details on the Construction of Citation Graphs

Appendix C Graph Terminology, Definitions, and Descriptions

Appendix D Appendix References