# Results

The updated searches returned 1,364 abstracts, of which 77 were retrieved and reviewed in full text (Figure 1). After excluding overlapping publications and together with the studies identified in our previous report, 18 independent RCTs (described in 23 publications5-20,49-55 and 11 prospective cohorts21-30,56 were eligible.

Figure 1 Literature search and selection

Shown is the literature flow. Searches of MEDLINE and the Cochrane Central register returned 1364 citations. 1287 were excluded at the abstract level, and 77 were reviewed in full text. After full text review and including 14 studies from our previous systematic review, we finally included 34 papers (11 on prospective cohorts and 18 on randomized trials).

## Randomized Controlled Trials

Of the 18 eligible trials, 13 were conducted in Europe, three in the United States, one in Japan and one in India (Table 1). Twelve trials enrolled patients with a history of heart disease6,7,9,11-15,17-19,50,54,55 (Group 1), three enrolled patients with claudication10 or hypercholesterolemia20,49 (Group 2), and three included patients with implantable defibrillators (Group 3).5,8,16 The majority included predominantly male patients with mean ages in the early sixties. No trial adequately described the distribution of EPA or DHA intake at baseline, but two trials reported average serum EPA and DHA measurements suggesting low mean intake at baseline (e.g., corresponding to less than one fish per week).8,20 In the intervention arms, supplementation included purified EPA and DHA (ethyl esters), EPA alone, or fish oil. In the RCTs daily supplement doses ranged from approximately 0.27 to 6 grams. Control arms received a variety of non-marine oils (Table 1).

Table 1 Randomized controlled trials of the effects of long chain n-3 fatty acid supplements on mortality phenotypes

Study (Year), Country (Reference) | Mean age [y] (males [%]) | Population | Baseline EPA +DHA | Intervention | | Control | | Quality items:
Study (Year), Country (Reference) | Mean age [y] (males [%]) | Population | Baseline EPA +DHA | N | Description | N | Description | A | B | C | D | E
Group 1 (patients with history of coronary artery disease or myocardial infarction)
von Schacky (1999), Germany (19) | 59 (76) | CAD | ND | 111 | EPA+DHA (3.4 g/d for 3 mo, then 1.7 g/d for 21 mo)^1^ | 112 | Equivalent dose of mixed FA; no marine n-3 FA | Y | Y | Y | N | Y
Sacks (1995), United States (17) | 62 (93) | CAD | ND | 31 | EPA+DHA (6 g/d)^2^ | 28 | Olive oil (6 g/d) | Y | Y | Y | Y | Y
Johansen (1999), Norway (6) | 60 (78) | CAD patients undergoing PTCA | 26% taking fish oil | 250 | EPA+DHA (5.1 g/d) | 250 | Placebo | Y | Y | Y | Y | Y
Calo (2005),Italy (9) | 66 (85) | Patients undergoing CABG | ND | 79 | EPA+DHA (1:2 ratio, 0.85 g/d) | 81 | Placebo | Y | N | N | N | Y
Durrington (2001), United Kingdom (7) | 59 (73) | CHD | ND | 30 | EPA (44%) +DHA (36%) from n-3 FA (4g/d)+ simvastatin | 29 | Corn oil (4g/d) + simvastatin | Y | Y | N | N | Y
Nilsen (2001), Norway (11) | 64 (80) | Recent MI | ND | 150 | EPA+DHA (1:2 ratio, from 4 g/d n-3 FA) | 150 | Corn oil (4 g/d) | Y | N | N | N | Y
GISSI-Prevenzione^3^(2002), Italy (12-14) | 60 (85) | Recent MI | ≤1fish/ week (73% of patients) | 5665 | EPA+DHA (1:2 ratio, 0.85 g/d) ± vitamin E (0.3 g/d) | 5658 | Vitamin E (0.3 g/d) or no supplement | Y | N | Y | N | Y
GISSI-HF (2008), Italy (15;51;52) | 67 (78) | Heart failure | ND | 3494 | EPA+DHA (1:2 ratio, 0.85 g/d) | 3481 | Placebo | Y | Y | N | N | Y
Singh^4^(1997), India (18) | 49 (93) | Recent MI | ND | 122 | EPA+DHA (1.8 g/d)^5^ | 118 | Aluminum hydroxide (0.1 g/d) | Y | Y | N | N | N
Rauch (2010), Germany (54) | 64 (74) | Recent MI | Fish intake significantly increased during study in both groups | 1940 | 1 g/d n-3-acid ethyl esters-90 (460 mg EPA; 380 mg DHA) | 1911 | Placebo olive oil (1g/d) | Y | Y | Y | N | Y
Galan (2010), France (55) | 61 (80) | Recent CHD | ND | 1253 | 400 mg EPA + 200 mg DHA | 1248 | Placebo | Y | Y | Y | N | Y
Kromhout (2010) Netherlands (50) | 69 (78)^7^ | MI in past 10 years | EPA + DHA: 125 mg/day | 2404 | Margarine (0.4 g/day of EPA-DHA in ratio of 3:2 w/ or w/o 2 g of ALA) | 2433 | Placebo margarine (w/ or w/o 2 g of ALA) | Y | Y | Y | N | Y
Group 2 (patients with intermittent claudication or hypercholesterolemia)
Leng (1998), Scotland (10) | 66 (68) | Claudication | ND | 60 | EPA (0.27 g/d) | 60 | Sunflower seed oil (3 g/d) | Y | Y | Y | N | Y
JELIS (2007), Japan (20;53) | 61 (32) | Hypercholesterolemia | Plasma EPA: 2.9 mol% | 9326 | EPA (1.8 g/d) + statins | 9319 | statins | Y | N | N | N | Y
Einvik (2010) Norway (49) | 70 (100)^7^ | Hypercholesterolemia | EPA 1.4% of FA intake; DHA 1.1% of FA intake | 282 | 2.4 g n-3 PUFA / day^8^ (w/ or w/o diet counselling) | 281 | Corn oil (w/ or w/o diet counselling) | Y | Y | Y | N | Y
Group 3 (patients with implantable cardioverter defibrillators)
Brouwer (2006), Europe^6^(8) | 62 (84) | Patients with ICD | Serum EPA 1.1% of cholesteryl esters | 273 | Fish oil (2 g/d) of fish oil^9^ | 273 | High-oleic acid sunflower oil (2 g/d) | Y | Y | N | N | Y
Leaf (2005), United States (5) | 66 (83) | Patients with ICD | EPA+DHA 3.5% of FA intake | 200 | EPA+DHA (2.6 g/d) from n-3 FA (4g/d) | 202 | Olive oil (4 g/d) | Y | Y | N | N | Y
Raitt (2005), United States (16) | 63 (86) | Patients with ICD | ≤1 fatty fish meal/week. | 100 | EPA+DHA (1.3g/d) from fish oil (1.8 g/d) | 100 | Placebo (olive oil: 73% oleic acid, 12% palmitic acid) | Y | N | Y | N | Y

For quality items, A= randomization mode, B=double blinding, C= less than 20% dropouts, D= valid diet assessment for assessing background exposure, E= Report without internal inconsistencies

Abbreviations: EPA = eicosapentaenoic acid; CAD = coronary artery disease; CHD = coronary heart disease; DHA = docosahexaenoic acid; ICD = Implantable cardioverter defibrillators; MI = myocardial infarction; GISSI-HF or -Prevenzione, Gruppo Italiano per lo Studio della Sopravvivenza nell’Infarto miocardico –Heart Failure or –Prevenzione; JELIS = Japan EPA Lipid Intervention Study; mo, months; FA, fatty acids; RR, relative risk

1 Fish oil concentrate (55% EPA+DHA) 6 grams/day for 3 months and 3 grams/day for 21 months

2 EPA 2.88 grams/day, DHA 1.92 grams/day and other (mainly DHA) 1.2 grams/day

3 Data on GISSI-Prevenzione were extracted from three publications. Main result data are from Marchioli, et al., 2002 and 2005.(12;13) Macchia, et al., 2005(14) reports on a subgroup with progressive impairment of left ventricular systolic function – which was used in sensitivity analyses.

4 This study was highly criticized (see text)(70;71)

5 EPA 1.08 grams/day and DHA 0.72 grams/day

6 Poland, Germany, the Netherlands, United Kingdom, Czech Republic, Belgium, Austria, Switzerland

7 For baseline characteristics, a weighted mean of intervention and placebo groups is reported.

8 2.4 grams n-3 fatty acids (49% EPA, 35% DHA, 3.5 mg tocopherols/gram) taken as 2 capsules twice a day.

9 EPA (464 mg) + DHA (335 mg) + other n-3 FA (162 mg)

The median RCT sample size was 451 (25^th^ percentile 200, 75^th^ percentile 3,851), with three trials having a sample size in excess of 5000. With the exception of two trials that were 28 days9 and 6 months6 in duration, the majority of trials ranged from 1 to 5 years. All RCTs reported details on mode of randomization. Blinding of both participants and outcome assessors was reported in 12 RCTs.5-8,10,15,17-19,50,54,55 Loss to follow up was reported as less than 20 percent in 10 trials (citations).6,10,12-14,16,17,19,50,54,55 No RCT provided an estimate of mean dietary EPA and DHA intakes at baseline, although two report using a validated dietary instrument to assess participants’ baseline intake.6,17 Finally, the publication by Singh, et al.,18 contained a number of internal discrepancies, suggesting suboptimal reporting, analyses, and study conduct, or the possibility of fraud by the first author.57 Because this publication was never retracted, we included the results in the main analyses and excluded the results from the subgroup analyses.

Figure 2 shows the meta-analysis of 17 RCTs (51,264 participants) with data on all-cause mortality. The summary random effects risk ratio was 0.95 (95% confidence interval, CI: 0.89, 1.01), with little evidence for between-study heterogeneity. Three trials contributed 72 percent (n=36,943) of the patients in the meta-analysis, and their summary relative risk was 0.94 (95% CI 0.85, 1.04; Table 2). A borderline statistically significant effect was observed in several subgroup analyses: in the 11 RCTs in patients with a history of coronary artery disease (Group 1; relative risk 0.93 with 95% CI 0.8, 0.99), the subgroup of six RCTs in which less than 20 percent of patients were lost to follow-up (relative risk 0.85 with 95% CI 0.76, 0.95), and the 13 studies conducted in countries with lower average intakes of EPA and DHA than Japan and Norway (relative risk 0.93, 95% CI 0.88, 0.99). Effects across subgroups did not differ beyond what was expected by chance (meta-regression analyses, (Table 2). There was no evidence for an association between treatment effect and supplement dose (relative risk changed by a factor of 1.00 per 0.20 grams per day increase in supplement dose, 95% CI 0.97, 1.03).

Figure 2 Randomized controlled trials of the effect of EPA and DHA supplementation on all-cause mortality

Group 1 includes studies in patients with history of coronary artery disease or myocardial infarction; Group 2 includes studies in patients with intermittent claudication or hypercholesterolemia; and Group 3 includes studies in patients with implantable cardioverter defibrillators.

CAD: coronary artery disease; CABG: coronary artery bypass grafting; CHF: chronic heart failure; High Chol: hypercholesterolemia; GISSI-P: GISSI-Prevenzione trial; ICD: implantable cardiac defibrillators; MI: myocardial infarction

Shown is a forest plot of a meta-analysis of randomized trials of EPA and DHA for all-cause mortality. Each study is depicted by a square (denoting the point estimate), and a horizontal line (denoting the accompanying 95% confidence interval). Three subgroups are shown: The first includes studies in patients with history of coronary artery disease or myocardial infarction; the second includes studies in patients with intermittent claudication or hypercholesterolemia; and the third includes studies in patients with implantable cardioverter defibrillators. The summary relative risk for the first subgroup is 0.93 (95% confidence interval, 0.88 to 0.99); for the second 0.90 (95% confidence interval, 0.59 to 1.39); and for the third 0.69 (95% confidence interval, 0.39, 1.23). The overall effect across all studies is 0.95 (95% confidence interval, 0.89, 1.01).

Table 2 Results of subgroup and sensitivity analyses in randomized trials

| All-cause mortality | | | | Cardiac mortality
| Studies (Patients) | RR (95% CI) | Meta-regression (P value) | Heterogeneity P value (I^2^%) | Studies (Patients) | RR (95% CI) | Meta-regression (P value) | Heterogeneity P value (I^2^%)
All studies | 17 (51264) | 0.95 (0.89, 1.01) | – | 0.39 (5) | 14 (48500) | 0.89 (0.83, 0.96)^*^ | – | 0.63 (0)
Subgroup analyses
Randomization mode clear
Yes | 17 (51264) | 0.95 (0.89, 1.01) | – | 0.39 (5) | 14 (48500) | 0.89 (0.83, 0.96)^*^ | – | 0.63 (0)
No | – | – | | – | – | – | | –
Double-blinding
Yes | 12 (20636) | 0.95 (0.89, 1.02) | 0.74 | 0.59 (0) | 10 (18032) | 0.91 (0.84, 0.99)^*^ | 0.24 | 0.53 (0)
No | 5 (30628) | 0.93 (0.77, 1.13) | | 0.12 (45) | 4 (30468) | 0.82 (0.70, 0.95)^*^ | | 0.75 (0)
Drop-out rates <20%
Yes | 11 (38839) | 0.97 (0.91, 1.03) | 0.09 | 0.45 (0) | 10 (36418) | 0.92 (0.84, 0.99)^*^ | 0.15 | 0.65 (0)
No | 6 (12425) | 0.85 (0.76, 0.95)^*^ | | 0.69 (0) | 4 (12082) | 0.79 (0.68, 0.93)^*^ | | 0.65 (0)
Population group^1^
Group 1 | 11 (30788) | 0.93 (0.88, 0.99)^*^ | 0.41 | 0.60 (0) | 9 (28144) | 0.89 (0.83, 0.96)^*^ | 0.62 | 0.49 (0)
Group 2 | 3 (19328) | 0.90 (0.59, 1.39) | | 0.18 (41) | 2 (19208) | 0.86 (0.55, 1.34) | | 0.47 (0)
Group 3 | 3 (1148) | 0.69 (0.39, 1.23) | | 0.29 (20) | 3 (1148) | 0.64 (0.35, 1.18) | | 0.41 (0)
Industry funding
Yes | 11 (42744) | 0.94 (0.84, 1.04) | 0.57 | 0.14 (33) | 10 (42521) | 0.89 (0.83, 0.96)^*^ | 0.92 | 0.69 (0)
No | 6 (8520) | 1.01 (0.85, 1.19) | | 0.93 (0) | 4 (5979) | 0.80 (0.54, 1.19) | | 0.23 (30)
Performed in the United States
Yes | 3 (661) | 0.72 (0.34, 1.53) | 0.5 | 0.29 (19) | 3 (661) | 0.76 (0.36, 1.64) | 0.74 | 0.52 (0)
No | 14 (50603) | 0.95 (0.89, 1.01) | | 0.37 (7) | 11 (47839) | 0.89 (0.83, 0.96)^*^ | | 0.50 (0)
Performed in Countries With Background Intake
Yes | 4 (20008) | 0.91 (0.64, 1.29) | 0.4 | 0.23 (31) | 4 (20008) | 0.85 (0.57, 1.27) | 0.92 | 0.73 (0)
No | 13 (31256) | 0.93 (0.88, 0.99)^*^ | | 0.52 (0) | 10 (28492) | 0.88 (0.80, 0.96)^*^ | | 0.39 (5)
Study size
Exclude 3 largest studies^2^ | 14 (14321) | 0.99 (0.86, 1.13) | 0.75 | 0.57 (0) | 11 (11557) | 0.83 (0.67, 1.02) | 0.56 | 0.62 (0)
Only 3 largest studies | 3 (36943) | 0.94 (0.85, 1.04) | | 0.09 (59) | 3 (36943) | 0.89 (0.82, 0.98)^*^ | | 0.33 (9)
Internal inconsistencies
Yes | – | – | – | – | 1 (240) | 0.52 (0.28, 0.95)^*^ | 0.11 | –
No | – | – | | – | 13 (48260) | 0.90 (0.83, 0.97)^*^ | | 0.81 (0)

* p<0.05

1 Group 1: patients with coronary artery diseases, undergoing coronary artery bypass surgery or with recent myocardial infarction; Group 2: patients with intermittent claudication or hypercholesterolemia; Group 3: patients with implantable cardioverter defibrillators.

2 GISSI-Prevenzione, (12-14) GISSI-Heart Failure(15;51;52) and JELIS.(20;53)

In the meta-analysis of 14 trials (48,500 patients) with data on cardiac mortality, the relative risk was 0.89 (95% CI, 0.83, 0.96) favoring supplementation (Figure 3). There was no evidence of between-study heterogeneity based on Cochran’s Q and the I^2^ statistic. The point estimates of the relative risks were similar across subgroups (Table 2). In subgroup analyses the relative risks of cardiac mortality remained statistically significant in several subgroups, including trials performed in countries with presumed lower background intakes, and trials in patients with a history of coronary artery disease (Group 1). Excluding the trial by Singh, et al.,18 that had internal inconsistencies and a large effect size (relative risk 0.50), did not affect the summary estimate. No differences in the effects in each subgroup in meta-regression analyses were statistically significant (Table 2). Again, there the treatment effect was not associated with supplement dose beyond what would be expected by chance (relative risk changed by a factor of 0.99 per 0.20 grams per day increase in supplement dose, 95% CI 0.95, 1.02).

Figure 3 Randomized controlled trials of the effect of EPA and DHA supplementation on cardiac mortality

Group 1 includes studies in patients with history of coronary artery disease or myocardial infarction; Group 2 includes studies in patients with intermittent claudication or hypercholesterolemia; and Group 3 includes studies in patients with implantable cardioverter defibrillators.

CAD: coronary artery disease; CABG: coronary artery bypass grafting; CHF: chronic heart failure; High Chol: hypercholesterolemia; GISSI-P: GISSI-Prevenzione trial; ICD: implantable cardiac defibrillators; MI: myocardial infarction

Shown is a forest plot of a meta-analysis of randomized trials of EPA and DHA for cardiac mortality. Each study is depicted by a square (denoting the point estimate), and a horizontal line (denoting the accompanying 95% confidence interval). Three subgroups are shown: The first includes studies in patients with history of coronary artery disease or myocardial infarction; the second includes studies in patients with intermittent claudication or hypercholesterolemia; and the third includes studies in patients with implantable cardioverter defibrillators. The summary relative risk for the first subgroup is 0.89 (95% confidence interval, 0.83 to 0.96); for the second 0.86 (95% confidence interval, 0.55 to 1.34); and for the third 0.64 (95% confidence interval, 0.35, 1.18). The overall effect across all studies is 0.89 (95% confidence interval, 0.83, 0.96).

## Prospective Cohort Studies

Of the 11 eligible prospective cohort studies, two23,28 that did not report sufficient data were excluded from quantitative analyses (Table 3). All nine remaining studies included participants without prior history of cardiovascular disease. EPA and DHA intake was estimated from fish consumption using frequency questionnaires in six studies and dietary history questionnaires in two studies. Mean or median daily intakes ranged from 0.04 to approximately 0.90 grams, the highest intake corresponding to a Japanese cohort.27 The higher intake category (percentile) threshold was slightly under 0.30 grams per day in cohorts from China22 and the United States.25

Table 3 Prospective cohort studies (general population) on the effects of EPA and DHA consumption on mortality phenotypes

Author, Year, Country (Reference) | Sample size | Males (%) | Age mean (range), [y] | Dietary assessment | EPA, DHA intake (g/d)^1^ | Duration (y) | Outcome (ascertainment) | Adjustments | Quality assessment
Author, Year, Country (Reference) | Sample size | Males (%) | Age mean (range), [y] | Dietary assessment | EPA, DHA intake (g/d)^1^ | Duration (y) | Outcome (ascertainment) | Adjustments
| | | | | | | | | A | B | C | D | E | F | G | H | I
Studies reporting on cardiac or cardiovascular death
Pietinen et al, 1997, Finland(21) | 21930 | 100 | NR (50-69) | FFQ | 0.4 | 6.1 | Coronary death from central population register, death certificates | DEM, SES, ANTHRO, HEALTH, LIFE, NUTRIENT, ENERGY, OTHER | Y | Y | Y | Y | Y | Y | Y | Y | Y
De Goede et al, 2010,Netherlands(56) | 21342 | 45 | 42 (20-65) | FFQ | 0.1 | 11.3 | CHD death from registry | DEM, ENERGY, LIFE, SES, NUTRIENT | Y | Y | Y | Y | Y | Y | Y | Y | Y
Yuan et al, 2001, China(22) | 18244 | 100 | 56 (45-64) | FFQ | 0.1 | 12 | Acute MI death from death certificates | DEM, SES, ANTHRO, HEALTH, LIFE, ENERGY | Y | Y | Y | Y | Y | Y | Y | Y | Y
Kamphuis et al, 2006, Netherlands(24) | 2574 | 100 | NR( 70-90) | Dietary history method | 0.1 | 10 | CVD death from general practitioners, hospital registries | DEM, SES, ANTHRO, HEALTH, LIFE, ENERGY | Y | N | N | N | Y | Y | Y | NR | Y
Studies reporting on cardiac, cardiovascular or sudden cardiac death
Iso et al, 2006, Japan (27) | 33262 | 48 | NR (40-59) | FFQ | 0.9 | 10 | Sudden cardiac death (ND) | DEM, SES, ANTHRO, HEALTH, LIFE, NUTRIENT, ENERGY | Y | Y | Y | Y | Y | Y | Y | Y | Y
Albert et al, 1998, United States (25) | 20551 | 100 | NR (40-84) | FFQ | 0.3 | 11 | Sudden death from medical records, reports from next of kin | DEM, ANTHRO, HEALTH, LIFE, NUTRIENT, OTHER | Y | Y | Y | Y | Y | Y | Y | Y | Y
Studies reporting on all-cause deaths
Folsom et al. 2004, United States (29) | 41835 | 0 | 54 (55-69) | FFQ | 0.1 | 14 | All-cause deaths from questionnaires, death records, national death index | DEM, SES, ANTHRO, HEALTH, LIFE, NUTRIENT, ENERGY | Y | Y | N | Y | Y | Y | Y | Y | Y
Nagata et al, 2002, Japan (30) | 29080 | 46 | 55 (35-NR) | FFQ | 0.8 | 7 | All-cause deaths (ND) | DEM, ANTHRO, HEALTH, LIFE, ENERGY | Y | Y | N | Y | Y | Y | Y | Y | Y
Studies that do not report sufficient data for meta-regression
Dolecek et al., 1992, United States (23) | 6250 | 100 | (35-57) | Multiple 24-hrdietary recall | 0.04 | 10.5 | All-cause and CHD mortality (National Death Index, death certificates) | DEM, HEALTH, LIFE | Y | Y | Y | NR | Y | Y | Y | Y | N
Kaushik et al, 2008, Australia (28) | 2683 | 56 | 49 | FFQ | ND | 10 | CHD death | DEM, SES, ANTHRO, HEALTH, LIFE, ENE | Y | Y | Y | N | N | NR | Y | Y | Y

Abbreviations: FA = Fatty acids; FFQ = Food frequency questionnaire; US = United States; BMI = Body mass index; CHD = Coronary heart disease; HDL= High density lipoprotein; DEM = Demographics; SES = Socio-economic status; ANTHRO = Anthropometric data; HEALTH = health or disease conditions; LIFE = lifestyle variables such as smoking, alcohol consumption, or physical activity; NUTRIENT = other nutrient intakes; NR, Not reported

For quality assessment: A, unbiased cohort selection; B, large sample size (>10000), C, adequate description of participants, D: validated dietary assessment method, E: Quantification of the type and amount of long chain n-3 fatty acid intakes, F: adequate method to ascertain clinical outcome, G: long follow-up period (at least 5 years), H: completeness of data throughout follow-up (at least for 80 percent of participants), I: Multivariate analyses adjusted for energy or nutritional variables

1 Mean or median intake of EPA and DHA

All prospective cohorts described unbiased selection of subjects and had follow-up periods ranging from 6.1 to 21.5 years (Table 3). Eight out of 11 cohorts enrolled at least 10,000 participants. At the end of the observation period survival status was available for at least 80 percent of participants for all except one study.24 All except one study24 reported using a validated method to assess EPA and DHA intake and survival status, and performed multivariate analyses adjusting for potential confounders. The outcome of interest was cardiac or cardiovascular mortality in 5 studies (6 meta-regression entries as Jarvinen, et al.,26 reported separate data per sex), sudden cardiac death in two, and all cause mortality in the remaining two.

Table 4 shows the results of linear and piecewise linear (splined) dose-response meta-regression analyses for increasingly broader definitions for mortality: cardiac or cardiovascular (left most panel, 6 meta-regression entries); cardiac, cardiovascular or sudden cardiac death (middle panel, 8 meta-regression entries); and all-cause (rightmost panel, 10 meta-regression entries). Overall, in meta-regression analyses (Figure 4) based on adjusted data (main analyses) we identified a statistically significant association between increasing mean EPA or DHA intake up to 0.20 grams per day and decreased risk of cardiac, cardiovascular or sudden cardiac death (odds ratio 0.64 per 0.20 grams average daily intake, 95% CI: 0.45 to 0.89), with no change in the risk at higher mean intakes where the odds ratio is 1.00 (Table 4; p=0.03 for joint testing of both mean intake variables, above or below the spline threshold). Associations in the same direction were not statistically significant for other combinations of definitions of mortality and thresholds for linear splines. In meta-regressions using unadjusted data the risk of any death increased with higher mean EPA or DHA intakes beyond what would be expected by chance (Table 4); however, this may be indicative of confounding. Overall, there is no evidence for substantial heterogeneity in the strength of the association across studies, as the estimated standard deviation of the study-specific slopes is very small (<10^-5^) in all analyses.

Table 4 Dose-response meta-regression analyses in prospective cohort studies

Definition of mortality (references) Strata (Participants) | Threshold (grams/day) | Relative OR (95% CI ) per 0.20 g/day in mean intake
Definition of mortality (references) Strata (Participants) | Threshold (grams/day) | Relative ORadj | Pintake, adj | Relative ORunadj | Pintake, unadj
Cardiac or cardiovascular mortality (21;22;24;26;56) 6 (69309) | — (linear) | 0.99 (0.96, 1.03) | 0.753 | 1.01 (0.98, 1.05) | 0.423
Cardiac or cardiovascular mortality (21;22;24;26;56) 6 (69309)
Cardiac or cardiovascular mortality (21;22;24;26;56) 6 (69309) | ≤0.20 | 0.70 (0.48, 1.02) | 0.184 | 0.69 (0.49, 0.97) | 0.066
Cardiac or cardiovascular mortality (21;22;24;26;56) 6 (69309) | >0.20 | 1.00 (0.97, 1.04) | | 1.02 (0.99, 1.06)
Cardiac or cardiovascular mortality (21;22;24;26;56) 6 (69309)
Cardiac or cardiovascular mortality (21;22;24;26;56) 6 (69309) | ≤0.30 | 0.93 (0.77, 1.13) | 0.752 | 0.89 (0.74, 1.06) | 0.242
Cardiac or cardiovascular mortality (21;22;24;26;56) 6 (69309) | >0.30 | 1.00 (0.96, 1.04) | | 1.03 (0.99, 1.07)
Cardiac or cardiovascular mortality (21;22;24;26;56) 6 (69309)
Cardiac or cardiovascular mortality (21;22;24;26;56) 6 (69309) | ≤0.40 | 1.03 (0.91, 1.15) | 0.813 | 0.98 (0.88, 1.10) | 0.626
Cardiac or cardiovascular mortality (21;22;24;26;56) 6 (69309) | >0.40 | 0.99 (0.94, 1.03) | | 1.02 (0.98, 1.07)
Cardiac or cardiovascular mortality (21;22;24;26;56) 6 (69309)
Cardiac or cardiovascular mortality (21;22;24;26;56) 6 (69309) | ≤0.50 | 1.03 (0.95, 1.13) | 0.569 | 1.00 (0.93, 1.09) | 0.701
Cardiac or cardiovascular mortality (21;22;24;26;56) 6 (69309) | >0.50 | 0.98 (0.93, 1.03) | | 1.02 (0.97, 1.07)
Cardiac or cardiovascular mortality (21;22;24;26;56) 6 (69309)
Cardiac, cardiovascular or sudden cardiac death mortality (21;22;24-27;56) 8 (123122) | — (linear) | 0.99 (0.96, 1.03) | 0.749 | 1.02 (0.99, 1.05) | 0.196
Cardiac, cardiovascular or sudden cardiac death mortality (21;22;24-27;56) 8 (123122)
Cardiac, cardiovascular or sudden cardiac death mortality (21;22;24-27;56) 8 (123122) | ≤0.20 | 0.64 (0.46, 0.89)^*^ | 0.030 | 0.95 (0.73, 1.25) | 0.383
Cardiac, cardiovascular or sudden cardiac death mortality (21;22;24-27;56) 8 (123122) | >0.20 | 1.00 (0.97, 1.04) | | 1.02 (0.99, 1.06)
Cardiac, cardiovascular or sudden cardiac death mortality (21;22;24-27;56) 8 (123122)
Cardiac, cardiovascular or sudden cardiac death mortality (21;22;24-27;56) 8 (123122) | ≤0.30 | 0.88 (0.74, 1.05) | 0.357 | 0.97 (0.83, 1.14) | 0.350
Cardiac, cardiovascular or sudden cardiac death mortality (21;22;24-27;56) 8 (123122) | >0.30 | 1.01 (0.97, 1.05) | | 1.03 (0.99, 1.06)
Cardiac, cardiovascular or sudden cardiac death mortality (21;22;24-27;56) 8 (123122)
Cardiac, cardiovascular or sudden cardiac death mortality (21;22;24-27;56) 8 (123122) | ≤0.40 | 1.00 (0.89, 1.11) | 0.950 | 1.01 (0.91, 1.13) | 0.427
Cardiac, cardiovascular or sudden cardiac death mortality (21;22;24-27;56) 8 (123122) | >0.40 | 0.99 (0.95, 1.04) | | 1.02 (0.98, 1.07)
Cardiac, cardiovascular or sudden cardiac death mortality (21;22;24-27;56) 8 (123122)
Cardiac, cardiovascular or sudden cardiac death mortality (21;22;24-27;56) 8 (123122) | ≤0.50 | 1.02 (0.94, 1.10) | 0.815 | 1.02 (0.94, 1.10) | 0.431
Cardiac, cardiovascular or sudden cardiac death mortality (21;22;24-27;56) 8 (123122) | >0.50 | 0.98 (0.94, 1.03) | | 1.02 (0.98, 1.07)
Cardiac, cardiovascular or sudden cardiac death mortality (21;22;24-27;56) 8 (123122)
All-cause mortality (21;22;24-27;29;30;56) 10 (194037) | — (linear) | 0.99 (0.97, 1.01) | 0.311 | 1.03 (1.01, 1.05) | 0.003
All-cause mortality (21;22;24-27;29;30;56) 10 (194037)
All-cause mortality (21;22;24-27;29;30;56) 10 (194037) | ≤0.20 | 0.98 (0.89, 1.08) | 0.593 | 0.97 (0.89, 1.06) | 0.004
All-cause mortality (21;22;24-27;29;30;56) 10 (194037) | >0.20 | 0.99 (0.97, 1.01) | | 1.04 (1.01, 1.06)
All-cause mortality (21;22;24-27;29;30;56) 10 (194037)
All-cause mortality (21;22;24-27;29;30;56) 10 (194037) | ≤0.30 | 0.98 (0.92, 1.05) | 0.581 | 0.96 (0.90, 1.02) | <0.001
All-cause mortality (21;22;24-27;29;30;56) 10 (194037) | >0.30 | 0.99 (0.97, 1.01) | | 1.04 (1.02, 1.07)
All-cause mortality (21;22;24-27;29;30;56) 10 (194037)
All-cause mortality (21;22;24-27;29;30;56) 10 (194037) | ≤0.40 | 0.99 (0.94, 1.04) | 0.597 | 0.97 (0.93, 1.01) | <0.001
All-cause mortality (21;22;24-27;29;30;56) 10 (194037) | >0.40 | 0.99 (0.96, 1.01) | | 1.05 (1.03, 1.07)
All-cause mortality (21;22;24-27;29;30;56) 10 (194037)
All-cause mortality (21;22;24-27;29;30;56) 10 (194037) | ≤0.50 | 0.99 (0.95, 1.03) | 0.599 | 0.98 (0.95, 1.02) | <0.001
All-cause mortality (21;22;24-27;29;30;56) 10 (194037) | >0.50 | 0.99 (0.96, 1.02) | | 1.06 (1.03, 1.08)

Jarvinen et al. (26) reported separate data per sex, and has been entered as two strata (two meta-regression entries) in the analyses. For each mortality phenotype definition we performed a linear and four piecewise linear spline meta-regressions. In the splined dose response analyses we allowed separate linear dose-response relationships below or above a threshold of 0.20 through 0.50 grams of mean EPA and DHA intake per day. In each row, the first number is the slope for average mean intakes up to the threshold (0.20 to 0.50 grams per day); the second number is the slope for average intakes in excess of the threshold.

Relative OR_adj_ (OR_unadj_): Relative odds ratio per 0.20 grams per day of higher mean intake using adjusted data (using unadjusted data); P_intake, adj_ (P_intake, adj_): p-value for the association of mean EPA or DHA daily intake with the probability of dying (for splined models this comes from joint testing of both mean intake variables, above or below the spline threshold)

Figure 4 Meta-regression analyses

The three columns display three alternative definitions of mortality. The upper row (A) shows dose-response meta-regressions assuming a linear dose response relationship throughout the range of mean intakes of EPA and DHA. The lower row (B) shows corresponding meta-regressions assuming different linear relationships with mean dose above or below a threshold of 0.20 grams per day. See Table 4 for results using alternative thresholds.

The figure has 6 panels, arranged in 3 columns and 2 rows. Each panel is a meta-regression plot showing the relationship between the probability of dying and the mean EPA or DHA intake in grams per day in the various intake groups of prospective cohort studies. The three columns of panels correspond to alternative definitions of mortality: Cardiac or cardiovascular mortality on the left; cardiac, cardiovascular or sudden cardiac death mortality in the middle; and all-cause mortality on the right. The upper row shows dose-response meta-regressions assuming a linear dose response relationship throughout the range of mean intakes of EPA or DHA. The lower row shows corresponding meta-regressions assuming different linear relationships with mean dose above or below a threshold of 0.20 grams per day. The linear models in the top row and the spline model for all cause mortality (bottom row on the right) show no evidence of association between mean EPA or DHA intake and the probability of death. However, the splined models for cardiac or cardiovascular mortality (bottom row on the left), and cardiac, cardiovascular mortality or sudden cardiac death mortality (bottom row on the right) are consistent with a decreasing probability of death for mean intakes of EPA or DHA up to 0.20 grams per day, with no further effect on the risk of mortality for higher mean intakes.

Finally, there were no statistically significant interactions between quality items and the mean EPA and DHA intake in any of the above analyses (all p-values for the dose-response-by-quality item interaction effects were above 0.55).