# References

1 Bang HO, Dyerberg J, Sinclair HM. The composition of the Eskimo food in north western Greenland. Am J Clin Nutr. 1980;33:2657-61. [pmid: 7435433].
2 Dyerberg J, Bang HO, Stoffersen E, Moncada S, Vane JR. Eicosapentaenoic acid and prevention of thrombosis and atherosclerosis?. Lancet. 1978;2:117-9. [pmid: 78322].
3 Kris-Etherton PM, Harris WS, Appel LJ. Fish consumption, fish oil, omega-3 fatty acids, and cardiovascular disease. Circulation. 2002;106:2747-57. [pmid: 12438303].
4 Mozaffarian D, Rimm EB. Fish intake, contaminants, and human health: evaluating the risks and the benefits. JAMA. 2006;296:1885-99. [pmid: 17047219].
5 Leaf A, Albert CM, Josephson M, et al. Prevention of fatal arrhythmias in high-risk subjects by fish oil n-3 fatty acid intake. Circulation. 2005;112:2762-8. [pmid: 16267249].
6 Johansen O, Seljeflot I, Hostmark AT, Arnesen H. The effect of supplementation with omega-3 fatty acids on soluble markers of endothelial function in patients with coronary heart disease. Arterioscler Thromb Vasc Biol. 1999;19:1681-6. [pmid: 10397685].
7 Durrington PN, Bhatnagar D, Mackness MI, et al. An omega-3 polyunsaturated fatty acid concentrate administered for one year decreased triglycerides in simvastatin treated patients with coronary heart disease and persisting hypertriglyceridaemia. Heart. 2001;85:544-8. [pmid: 11303007].
8 Brouwer IA, Zock PL, Camm AJ, et al. Effect of fish oil on ventricular tachyarrhythmia and death in patients with implantable cardioverter defibrillators: the Study on Omega-3 Fatty Acids and Ventricular Arrhythmia (SOFA) randomized trial. JAMA. 2006;295:2613-9. [pmid: 16772624].
9 Calo L, Bianconi L, Colivicchi F, et al. N-3 Fatty acids for the prevention of atrial fibrillation after coronary artery bypass surgery: a randomized, controlled trial. J Am Coll Cardiol. 2005;45:1723-8. [pmid: 15893193].
10 Leng GC, Lee AJ, Fowkes FG, et al. Randomized controlled trial of gamma-linolenic acid and eicosapentaenoic acid in peripheral arterial disease. Clin Nutr. 1998;17:265-71. [pmid: 10205349].
11 Nilsen DW, Albrektsen G, Landmark K, Moen S, Aarsland T, Woie L. Effects of a high-dose concentrate of n-3 fatty acids or corn oil introduced early after an acute myocardial infarction on serum triacylglycerol and HDL cholesterol. Am J Clin Nutr. 2001;74:50-6. [pmid: 11451717].
12 Marchioli R, Barzi F, Bomba E, et al. Early protection against sudden death by n-3 polyunsaturated fatty acids after myocardial infarction: time-course analysis of the results of the Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto Miocardico (GISSI)-Prevenzione. Circulation. 2002;105:1897-903. [pmid: 11997274].
13 Marchioli R, Levantesi G, Macchia A, et al. Antiarrhythmic mechanisms of n-3 PUFA and the results of the GISSI-Prevenzione trial. J Membr Biol. 2005;206:117-28. [pmid: 16456722].
14 Macchia A, Levantesi G, Franzosi MG, et al. Left ventricular systolic dysfunction, total mortality, and sudden death in patients with myocardial infarction treated with n-3 polyunsaturated fatty acids. Eur J Heart Fail. 2005;7:904-9. [pmid: 16087142].
15 Tavazzi L, Maggioni AP, Marchioli R, et al. Effect of n-3 polyunsaturated fatty acids in patients with chronic heart failure (the GISSI-HF trial): a randomised, double-blind, placebo-controlled trial. Lancet. 2008;372:1223-30. [pmid: 18757090].
16 Raitt MH, Connor WE, Morris C, et al. Fish oil supplementation and risk of ventricular tachycardia and ventricular fibrillation in patients with implantable defibrillators: a randomized controlled trial. JAMA. 2005;293:2884-91. [pmid: 15956633].
17 Sacks FM, Stone PH, Gibson CM, Silverman DI, Rosner B, Pasternak RC. Controlled trial of fish oil for regression of human coronary atherosclerosis. HARP Research Group. J Am Coll Cardiol. 1995;25:1492-8. [pmid: 7759696].
18 Singh RB, Niaz MA, Sharma JP, Kumar R, Rastogi V, Moshiri M. Randomized, double-blind, placebo-controlled trial of fish oil and mustard oil in patients with suspected acute myocardial infarction: the Indian experiment of infarct survival--4. Cardiovasc Drugs Ther. 1997;11:485-91. [pmid: 9310278].
19 von SC, Angerer P, Kothny W, Theisen K, Mudra H. The effect of dietary omega-3 fatty acids on coronary atherosclerosis. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 1999;130:554-62. [pmid: 10189324].
20 Yokoyama M, Origasa H, Matsuzaki M, et al. Effects of eicosapentaenoic acid on major coronary events in hypercholesterolaemic patients (JELIS): a randomised open-label, blinded endpoint analysis. Lancet. 2007;369:1090-8. [pmid: 17398308].
21 Pietinen P, Ascherio A, Korhonen P, et al. Intake of fatty acids and risk of coronary heart disease in a cohort of Finnish men. The Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study. Am J Epidemiol. 1997;145:876-87. [pmid: 9149659].
22 Yuan JM, Ross RK, Gao YT, Yu MC. Fish and shellfish consumption in relation to death from myocardial infarction among men in Shanghai, China. Am J Epidemiol. 2001;154:809-16. [pmid: 11682363].
23 Dolecek TA. Epidemiological evidence of relationships between dietary polyunsaturated fatty acids and mortality in the multiple risk factor intervention trial. Proc Soc Exp Biol Med. 1992;200:177-82. [pmid: 1579579].
24 Kamphuis MH, Geerlings MI, Tijhuis MA, Kalmijn S, Grobbee DE, Kromhout D. Depression and cardiovascular mortality: a role for n-3 fatty acids?. Am J Clin Nutr. 2006;84:1513-7. [pmid: 17158437].
25 Albert CM, Hennekens CH, O'Donnell CJ, et al. Fish consumption and risk of sudden cardiac death. JAMA. 1998;279:23-8. [pmid: 9424039].
26 Jarvinen R, Knekt P, Rissanen H, Reunanen A. Intake of fish and long-chain n-3 fatty acids and the risk of coronary heart mortality in men and women. Br J Nutr. 2006;95:824-9. [pmid: 16571163].
27 Iso H, Kobayashi M, Ishihara J, et al. Intake of fish and n3 fatty acids and risk of coronary heart disease among Japanese: the Japan Public Health Center-Based (JPHC) Study Cohort I. Circulation. 2006;113:195-202. [pmid: 16401768].
28 Kaushik S, Wang JJ, Flood V, Liew G, Smith W, Mitchell P. Frequency of fish consumption, retinal microvascular signs and vascular mortality. Microcirculation. 2008;15:27-36. [pmid: 17907016].
29 Folsom AR, Demissie Z. Fish intake, marine omega-3 fatty acids, and mortality in a cohort of postmenopausal women. Am J Epidemiol. 2004;160:1005-10. [pmid: 15522857].
30 Nagata C, Takatsuka N, Shimizu H. Soy and fish oil intake and mortality in a Japanese community. Am J Epidemiol. 2002;156:824-31. [pmid: 12397000].
31 Hooper L, Thompson RL, Harrison RA, et al. Risks and benefits of omega 3 fats for mortality, cardiovascular disease, and cancer: systematic review. BMJ. 2006;332:752-60. [pmid: 16565093].
32 Hooper L. Meta-analysis of RCTs finds that increasing consumption of polyunsaturated fat as a replacement for saturated fat reduces the risk of coronary heart disease. Evid Based Med. 2010;15:108-9. [pmid: 20682725].
33 Marik PE, Varon J. Omega-3 dietary supplements and the risk of cardiovascular events: a systematic review. Clin Cardiol. 2009;32:365-72. [pmid: 19609891].
34 Zhao YT, Chen Q, Sun YX, et al. Prevention of sudden cardiac death with omega-3 fatty acids in patients with coronary heart disease: a meta-analysis of randomized controlled trials. Ann Med. 2009;41:301-10. [pmid: 19148838].
35 Leon H, Shibata MC, Sivakumaran S, Dorgan M, Chatterley T, Tsuyuki RT. Effect of fish oil on arrhythmias and mortality: systematic review. BMJ. 2008;337:a2931. [pmid: 19106137].
36 Wang C, Harris WS, Chung M, et al. n-3 Fatty acids from fish or fish-oil supplements, but not alpha-linolenic acid, benefit cardiovascular disease outcomes in primary- and secondary-prevention studies: a systematic review. Am J Clin Nutr. 2006;84:5-17. [pmid: 16825676].
37 Konig A, Bouzan C, Cohen JT, et al. A quantitative analysis of fish consumption and coronary heart disease mortality. Am J Prev Med. 2005;29:335-46. [pmid: 16242600].
38 Hooper L, Thompson RL, Harrison RA, et al. Omega 3 fatty acids for prevention and treatment of cardiovascular disease. Cochrane Database Syst Rev. 2004:CD003177.
39 Bucher HC, Hengstler P, Schindler C, Meier G. N-3 polyunsaturated fatty acids in coronary heart disease: a meta-analysis of randomized controlled trials. Am J Med. 2002;112:298-304. [pmid: 11893369].
40 Wang C, Chung M, Balk EM, et al. Effects of omega-3 fatty acids on cardiovascular disease, Evidence Report/Technology Assessment No 94 (Prepared by Tufts-New England Medical Center Evidence-based Practice Center, underContract No 290-02-0022) AHRQ Publication No 04-E009-2. Rockville, MD. Agency for Healthcare Research and Quality. 2004.
41 Concato J, Shah N, Horwitz RI. Randomized, controlled trials, observational studies, and the hierarchy of research designs. N Engl J Med. 2000;342:1887-92. [pmid: 10861325].
42 Benson K, Hartz AJ. A comparison of observational studies and randomized, controlled trials. N Engl J Med. 2000;342:1878-86. [pmid: 10861324].
43 Sacks H, Chalmers TC, Smith H Jr. Randomized versus historical controls for clinical trials. Am J Med. 1982;72:233-40. [pmid: 7058834].
44 Chung M, Balk EM, Ip S, et al. Systematic review to support the development of nutrient reference intake values: challenges and solutions. Am J Clin Nutr. 2010;92:273-6. [pmid: 20504974].
45 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-88. [pmid: 3802833].
46 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21:1539-58. [pmid: 12111919].
47 Hamling J, Lee P, Weitkunat R, Ambuhl M. Facilitating meta-analyses by deriving relative effect and precision estimates for alternative comparisons from a set of estimates presented by exposure level or disease category. Stat Med. 2008;27:954-70. [pmid: 17676579].
48 Wallace BC, Schmid CH, Lau J, Trikalinos TA. Meta-Analyst: software for meta-analysis of binary, continuous and diagnostic data. BMC Med Res Methodol. 2009;9:80. [pmid: 19961608].
49 Einvik G, Klemsdal TO, Sandvik L, Hjerkinn EM. A randomized clinical trial on n-3 polyunsaturated fatty acids supplementation and all-cause mortality in elderly men at high cardiovascular risk. European Journal of Cardiovascular Prevention & Rehabilitation. 2010;17:588-92. [pmid: 20389249].
50 Kromhout D, Giltay EJ, Geleijnse JM. Alpha Omega Trial Group. n-3 fatty acids and cardiovascular events after myocardial infarction. New England Journal of Medicine. 2010;363:2015-26. [pmid: 20929341].
51 Marchioli R, Levantesi G, Silletta MG, et al. Effect of n-3 polyunsaturated fatty acids and rosuvastatin in patients with heart failure: results of the GISSI-HF trial. Expert Review of Cardiovascular Therapy. 2009;7:735-48. [pmid: 19589110].
52 Marchioli R, Silletta MG, Levantesi G, Pioggiarella R, Tognoni G. N-3 polyunsaturated fatty acids in heart failure: mechanisms and recent clinical evidence. Cellular & Molecular Biology. 2010;56:110-30. [pmid: 20196975].
53 Matsuzaki M, Yokoyama M, Saito Y, et al. Incremental effects of eicosapentaenoic acid on cardiovascular events in statin-treated patients with coronary artery disease. Circulation Journal. 2009;73:1283-90. [pmid: 19423946].
54 Rauch B, Schiele R, Schneider S, et al. OMEGA, a randomized, placebo-controlled trial to test the effect of highly purified omega-3 fatty acids on top of modern guideline-adjusted therapy after myocardial infarction. Circulation. 2010;122:2152-9. [pmid: 21060071].
55 Galan P, Kesse-Guyot E, Czernichow S, et al. Effects of B vitamins and omega 3 fatty acids on cardiovascular diseases: a randomised placebo controlled trial. BMJ. 2010;341:c6273. [pmid: 21115589].
56 de GJ, Geleijnse JM, Boer JM, Kromhout D, Verschuren WM. Marine (n-3) fatty acids, fish consumption, and the 10-year risk of fatal and nonfatal coronary heart disease in a large population of Dutch adults with low fish intake. Journal of Nutrition. 2010;140:1023-8. [pmid: 20335635].
57 Horton R. Expression of concern: Indo-Mediterranean Diet Heart Study. Lancet. 2005;366:354-6. [pmid: 16054927].
58 US Department of Agriculture and US Department of Health and HumanServices. Report of the Dietary Guidelines Advisory Committee on the dietary guidelines for Americans, 2010. (http://www.cnpp.usda.gov/DGAs2010-DGACReport.htm). 2010.
59 Lichtenstein AH, Appel LJ, Brands M, et al. Diet and lifestyle recommendations revision 2006: a scientific statement from the American Heart Association Nutrition Committee. Circulation. 2006;114:82-96. [pmid: 16785338].
60 Mozaffarian D, Shi P, Morris JS, et al. Mercury exposure and risk of cardiovascular disease in two U.S. cohorts. N Engl J Med. 2011;364:1116-25. [pmid: 21428767].
61 Dickersin K, Min YI. Publication bias: the problem that won't go away. Ann N Y Acad Sci. 1993;703:135-46. [pmid: 8192291].
62 Hopewell S, Loudon K, Clarke MJ, Oxman AD, Dickersin K. Publication bias in clinical trials due to statistical significance or direction of trial results. Cochrane Database Syst Rev. 2009. MR000006.
63 Russell R, Chung M, Balk EM, Atkinson S, Giovannucci E, Ip S, Taylor Mayne S, Raman G, Ross AC, Trikalinos T, West KP, Lau J. Issues and Challenges in Conducting Systematic Reviews to Support Development of Nutrient Reference Values: Workshop Summary: Nutrition Research Series, Vol. 2. 2009. Rockville (MD). Agency for Healthcare Research and Quality (US). Ref Type: Report.
64 Chan AW, Altman DG. Identifying outcome reporting bias in randomised trials on PubMed: review of publications and survey of authors. BMJ. 2005;330:753. [pmid: 15681569].
65 Chan AW, Krleza-Jeric K, Schmid I, Altman DG. Outcome reporting bias in randomized trials funded by the Canadian Institutes of Health Research. CMAJ. 2004;171:735-40. [pmid: 15451835].
66 Chan AW, Hrobjartsson A, Haahr MT, Gotzsche PC, Altman DG. Empirical evidence for selective reporting of outcomes in randomized trials: comparison of protocols to published articles. JAMA. 2004;291:2457-65. [pmid: 15161896].
67 Barlow RE, Bartolomew DJ, Bremner JM, Brunk HD. Statistical inference under order restrictions; the theory and application of isotonic regression. New York. Wiley. 1972.
68 Manson JE. Vitamin D and the heart: why we need large-scale clinical trials. Cleve Clin J Med. 2010;77:903-10. [pmid: 21147944].
69 Rauch B, Schiele R, Schneider S, et al. Highly purified omega-3 fatty acids for secondary prevention of sudden cardiac death after myocardial infarction-aims and methods of the OMEGA-study. Cardiovasc Drugs Ther. 2006;20:365-75. [pmid: 17124558].
70 White C. Suspected research fraud: difficulties of getting at the truth. BMJ. 2005;331:281-8. [pmid: 16052022].
71 Smith R. Investigating the previous studies of a fraudulent author. BMJ. 2005;331:288-91. [pmid: 16052023].