# Introduction

Since the seminal observation that Greenland Eskimos have lower cardiovascular disease mortality than genetically related Danes,1,2 adequate intake of fish or the fatty acids unique to fish, eicosopentanoic acid (EPA, 20:5n-3) and docosexaenoic acid (DHA, 22:6n-3), have been recommended to decrease risk.3,4 Potential mechanisms for reduced cardiovascular risk included anti-inflammatory, anti-thrombotic, antihypertensive, hypo-triglyceridemic and antiarrhythmic properties.5 A large body of clinical research is available to address issues related to defining a potential association or a causative link between EPA and DHA intake and clinical cardiovascular outcomes. Nonetheless, the results of several dozen prospective cohort studies and randomized trials,5-30 and several systematic reviews and meta-analyses generated from this body of work are inconsistent.31-40

In a previous systematic review we provided a qualitative synthesis of evidence from prospective cohorts and RCTs on the relationship between fish consumption and EPA and DHA intakes with cardiovascular clinical outcomes.36,40 While there was evidence that higher consumption of fish was associated with favorable clinical outcomes in cohorts, the corresponding data on EPA and DHA intakes was equivocal. On the basis of available data others concluded that for daily intakes of (combined) EPA and DHA in excess of 0.30 to 0.50 grams, the impact of EPA and DHA on cardiovascular mortality reaches a plateau, and that this could explain the different conclusions based on the data from various cohorts, or cohorts and RCTs.4 From this perspective, and in analogy to observations from clinical medicine,41-43 prospective cohorts and RCTs offer complementary information on the association of interest, as they refer to different intake (dose) levels and periods of observations.

We performed a systematic review and meta-analysis of evidence from prospective cohorts and RCTs on the relationship of EPA and DHA intakes with cardiovascular or all-cause mortality. Our aim was to assess the apparent congruence of these two types of study designs and to describe how randomized intervention trials and observational studies compare in their target populations, outcome definitions and results, with the intent to defining the dose-response relationships of EPA and DHA intakes to cardiovascular and all-cause mortality across diverse settings and wide ranges of intake levels.

## Subject and Methods

### Literature Search

We included all eligible prospective cohorts and randomized trials that were identified in our previous comprehensive systematic review, which was based on literature searches of MEDLINE and the Cochrane Central Register of Controlled trials through July 2005 (with no lower date limit).36,40 In addition, we updated this search from 2005 to May 2011 and supplemented the results with perusal of bibliographies from other systematic reviews. The exact search strategy is listed in the Systematic Review Protocol that accompanies this submission. Briefly, we used search terms for long chain polyunsaturated n-3 fatty acids (EPA and DHA) and fish oils, as well as terms related to cardiovascular disease. Searches were limited to English language publications and to humans.

### Eligibility Criteria

We included randomized controlled trials (with at least 4 weeks of intervention duration and less than 6 grams per day of EPA and DHA supplementation) and prospective cohorts (with at least 3 years of follow-up and at least 1000 participants) reporting on the association between EPA or DHA intake and various definitions of mortality, namely cardiac, cardiovascular, or all-cause mortality. For RCTs, the interventions of interest were EPA, DHA or fish oil (defining fish oils as EPA and DHA). For the prospective cohorts, our exposure of interest was dietary intake levels of EPA and DHA either as fish or supplements. Studies containing information on fish intake without reporting the amount of EPA and DHA or interventions that involved alpha-linolenic acid (ALA) only were excluded. Eligible were studies on human subjects with or without a history of cardiovascular disease (secondary or primary prevention settings, respectively). Two methodologists evaluated potentially relevant articles that met the eligibility criteria. Any disagreements were resolved by consensus or by a third arbitrator when consensus could not be reached.

## Data Extraction and Synthesis

Each study was extracted by a single investigator using piloted data-extraction forms. We did not contact primary study authors, and relied on the information reported in the publications. Data extraction included the following items: study design, population characteristics (country, mean age, gender distribution), type and intake or dosage of EPA and DHA, comparison groups (placebo or comparative control, when applicable), sample size, and outcomes of interest. We also extracted information on items related to methodological quality and on funding sources (described in a following paragraph). We accepted the definition of cardiac and cardiovascular mortality that was used in the primary studies. Typically, cardiac mortality was death ascribed to coronary heart disease or sudden cardiac death. Cardiovascular mortality also included vascular deaths (e.g., fatal strokes).

For RCTs we extracted number of events in the intervention and control groups. For prospective cohorts we recorded risk or hazard ratios for each quantile-category (i.e., tertiles, quartiles, or quintiles) of estimated DHA or EPA intake compared with a reference group. We also classified the adjustments performed in each prospective cohort into eight categories: demographic (i.e., age, marital status, race, gender, area); socio-economic (i.e., education, occupation); anthropometric (i.e., body mass index); health (i.e., cardiovascular disease, history of hypertension, diabetes, hypercholesterolemia or blood pressure); life style (i.e., smoking, alcohol consumption); nutrients (i.e., dietary intakes of cholesterol, saturated fat, omega-6 polyunsaturated fatty acids); energy (i.e., total energy intake), and other factors (i.e., treatment assignment).

## Grading Methodological Quality

We recorded the following items that have been proposed as indicative of methodological quality of RCTs: adequate description of randomization mode, use of double blinding (for participants and outcome assessors), proportion of dropouts, using valid methods to assess baseline intake, and discrepancies in the reporting of results.44 For prospective cohorts we assessed the following nine items: unbiased selection of the cohort; large sample size (more than 10,000 subjects); adequate description of the cohort; use of validated dietary assessment method; reporting of methods to estimate long chain omega-3 fatty acid intake; use of validated methods for ascertaining clinical outcomes; adequately long follow-up (at least 5 years); more than 80 percent completeness of follow-up; and analyses adjusting for energy.44

## Evidence Synthesis for Randomized Controlled Trials

We calculated summary relative risks by random effects meta-analysis using the DerSimonian and Laird model.45 We tested for between-study heterogeneity with the Q statistic (considered significant at the 0.10 level) and quantified its extent with the I^2^ statistic46 I^2^ ranges between 0 and 100 percent and expresses the proportion of between study variance that is attributable to heterogeneity rather than chance.

We further investigated potential associations of the treatment effect with study-level variables in subgroup analyses and random effects meta-regressions. Specifically, we examined country of origin (United States versus other; countries with high background intakes of EPA and DHA such as Japan and Norway versus other), randomization mode (adequately described versus not), double-blinding (used versus not used or not described), funding (any industry funding versus not), excessive drop-out rates (using 20 percent as threshold), supplementation dose (as a continuous variable, per 0.20 grams per day), and type of population (classified in three groups). The three population groups were: patients with history of coronary artery disease or myocardial infarction; patients with intermittent claudication or hypercholesterolemia; and patients with implantable cardioverter defibrillators.

## Evidence Synthesis for Prospective Cohorts

For each cohort study, we calculated statistics to perform dose-response meta-regressions. We back-calculated the “effective counts” of events in each category of EPA and DHA intake based on the pertinent adjusted log odds ratios (versus a reference intake category), their variance, and the total number of participants per intake category.47 The effective counts of events are such that when used in a logistic regression with the intake categories as the sole predictors they result in the same log odds ratios (coefficients), variances and covariances as those from the original adjusted model. If one started from the results of an unadjusted model, the effective counts would be identical to the actual counts of events.

The mean intake value per category of intake level is also needed for dose-response meta-regressions. When it was not reported, we selected the midpoint between intake category thresholds, and for the lowest and highest intake categories we imputed a mean intake 20 percent lower for the lowest quintile threshold or 20 percent higher for the highest quintile threshold, respectively. This method yielded very similar results to fitting a normal density over intake percentiles in two examples, and was retained for simplicity.

We then evaluated the association between cardiac or all-cause mortality and mean intake levels across all studies in meta-regression models. We performed two sets of analyses: We used a fixed intercept–fixed slope model, which is essentially a logistic regression with indicator variables for different studies. This analysis ignores any heterogeneity in the strength of the dose-response association (slopes) across studies, and is analogous to a fixed effects meta-analysis. We relaxed this assumption by also fitting a logistic mixed effects meta-regression (with fixed intercepts and random slopes), which explicitly models between-study variability in the strength of the dose-response relationship.

Further, we examined several different dose response relationships: a linear dose-response model and models that allowed different associations for mean intake levels above or below 0.20, 0.30, 0.40 or 0.50 grams per day (using a piecewise linear spline with a knot at the corresponding threshold). The latter splined analyses explicitly address the claim that the effects of EPA and DHA plateau at a low intake value.4 The above thresholds are in the same range as the intake of 0.30-0.50 grams of EPA and DHA per day currently recommended by the American Heart Association.3 We also performed meta-regressions using quality items as covariates interacting with the average EPA and DHA intake level (dose), to assess for relationships between the dose-response coefficients and study-level quality items.

## Software

Analyses were performed in Stata SE (version 11, Stata Corporation, College Station, Texas, U.S.) and Meta-Analyst (version 3 beta, Boston, U.S.).48 Unless otherwise stated, all tests are two-tailed and considered significant when p<0.05.