# Acknowledgements

The authors’ responsibilities were as follows:

- Trikalinos designed the research.
- Lee, Moorthy, Yu, and Chung conducted the research.
- Trikalinos and Lee performed statistical analysis.
- Trikalinos wrote the paper, which was critically commented on by all other authors.
- Trikalinos had primary responsibility for final content.
- All authors read and approved the final manuscript.