# References

1 Lichtenstein AH, Yetley EA, Lau J. Application of Systematic Review Methodology to the Field of Nutrition. J Nutr. 2008;138:2297-306. [pmid: 19022948].
2 Brannon P, Yetley E, Bailey R, Bailey R. Overview of the conference "Vitamin D and Health in the 21^st^ Century: an Update". Am J Clin Nutr. 2008;88.
3 National Institutes of Health and National Heart LaBI. Working group report on future clinical research directions on omega-3 fatty acids and cardiovascular disease. June. 2. 2004. Internet: http://www.nhlbi.nih.gov/meetings/workshops/omega-3/omega-3-rpt.htm. accessed 12/1/2008.
4 Blumberg-Kason S, Lipscomb R. Evidence-based nutrition practice guidelines: A valuable resource in the evidence analysis library. J Am Diet Assoc. 2006;106:1935-6. [pmid: 17126620].
5 Myers E. Systems for evaluating nutrition research for nutrition care guidelines: do they apply to population dietary guidelines?. J Am Diet Assoc. 2003;103:S34-S41. [pmid: 14666498].
6 CFSAN Office of Nutrition LaDS. Evidence-Based Review System for the Scientific Evaluation of Health Claims - Draft Guidance. July. 2007. Internet: http://www.cfsan.fda.gov/~dms/hclmgui5.html. accessed 12/1/2008.
7 Balk EM, Horsley TA, Newberry SJ, et al. A collaborative effort to apply the evidence-based review process to the field of nutrition: challenges, benefits, and lessons learned. Am J Clin Nutr. 2007;85:1448-56. [pmid: 17556679].
8 De Lorgeril M, Salen P. Fish and N-3 fatty acids for the prevention and treatment of coronary heart disease: nutrition is not pharmacology. Am J Med. 2002;112:316-9. [pmid: 11893373].
9 Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of Observational Studies in Epidemiology: A Proposal for Reporting. JAMA. 2000;283:2008-12. [pmid: 10789670].
10 Moher D, Cook DJ, Eastwood S, Olkin I, Rennie D, Stroup DF. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354:1896-900. [pmid: 10584742].
11 Lodge M, Becker L, van Binsbergen J, van Weel C, Rosser W. Organisation of a proposed Cochrane Diet and Nutrition Field. Eur J Clin Nutr. 2005;59(Suppl 1):S162-S166. [pmid: 16052185].
12 Becker LA, van Binsbergen JJ. How can a proposed Cochrane diet and nutrition field work effectively?. Eur J Clin Nutr. 2005;59(Suppl 1):S167-S171. [pmid: 16052186].
13 The EQUATOR Network. Enhancing the QUAlity and Transparancy Of Health Research. July. 2008. Internet: http://www.equator-network.org. assessed 12/1/2008.
14 Schaible UE, Kaufmann SH. Malnutrition and infection: complex mechanisms and global impacts. PLoS Med. 2007;4:e115. [pmid: 17472433].
15 Miller ER III, Pastor-Barriuso R, Dalal D, Riemersma RA, Appel LJ, Guallar E. Meta-analysis: high-dosage vitamin E supplementation may increase all-cause mortality. Ann Intern Med. 2005;142:37-46. [pmid: 15537682].
16 Duffield-Lillico AJ, Reid ME, Turnbull BW, et al. Baseline characteristics and the effect of selenium supplementation on cancer incidence in a randomized clinical trial: a summary report of the Nutritional Prevention of Cancer Trial. Cancer Epidemiol Biomarkers Prev. 2002;11:630-9. [pmid: 12101110].
17 Reid ME, Duffield-Lillico AJ, Garland L, Turnbull BW, Clark LC, Marshall JR. Selenium supplementation and lung cancer incidence: an update of the nutritional prevention of cancer trial. Cancer Epidemiol Biomarkers Prev. 2002;11:1285-91. [pmid: 12433704].
18 Hercberg S, Galan P, Preziosi P, et al. The SU.VI.MAX Study: a randomized, placebo-controlled trial of the health effects of antioxidant vitamins and minerals. Arch Intern Med. 2004;164:2335-42. [pmid: 15557412].
19 Wright ME, Lawson KA, Weinstein SJ, et al. Higher baseline serum concentrations of vitamin E are associated with lower total and cause-specific mortality in the Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study. Am J Clin Nutr. 2006;84:1200-7. [pmid: 17093175].
20 Spiegelman D, McDermott A, Rosner B. Regression calibration method for correcting measurement-error bias in nutritional epidemiology. Am J Clin Nutr. 1997;65:1179S-86S. [pmid: 9094918].
21 Beaton GH. Approaches to analysis of dietary data: relationship between planned analyses and choice of methodology. Am J Clin Nutr. 1994;59:253S-61S. [pmid: 8279436].
22 Izaks GJ. Fracture prevention with vitamin D supplementation: considering the inconsistent results. BMC Musculoskeletal Disorders. 2007;8:26. [pmid: 17349055].
23 Trumbo PR, Ellwood KC. Supplemental calcium and risk reduction of hypertension, pregnancy-induced hypertension, and preeclampsia: an evidence-based review by the US Food and Drug Administration. Nutr Rev. 2007;65:78-87. [pmid: 17345960].
24 van Mierlo LA, Arends LR, Streppel MT, et al. Blood pressure response to calcium supplementation: a meta-analysis of randomized controlled trials. J Hum Hyperten. 2006;20:571-80.
25 Winzenberg T, Shaw K, Fryer J, Jones G. Effects of calcium supplementation on bone density in healthy children: meta-analysis of randomised controlled trials. BMJ. 2006;333:775. [pmid: 16980314].
26 Davies AA, Davey SG, Harbord R, et al. Nutritional interventions and outcome in patients with cancer or preinvasive lesions: systematic review. J Natl Cancer Inst. 2006;98:961-73. [pmid: 16849679].
27 Trowman R, Dumville JC, Hahn S, Torgerson DJ. A systematic review of the effects of calcium supplementation on body weight. Br J Nutr. 2006;95:1033-8. [pmid: 16768823].
28 Gao X, LaValley MP, Tucker KL. Prospective studies of dairy product and calcium intakes and prostate cancer risk: a meta-analysis. J Natl Cancer Inst. 2005;97:1768-77. [pmid: 16333032].
29 Bischoff-Ferrari HA, Willett WC, Wong JB, Giovannucci E, Dietrich T, wson-Hughes B. Fracture prevention with vitamin D supplementation: a meta-analysis of randomized controlled trials. JAMA. 2005;293:2257-64. [pmid: 15886381].
30 Richy F, Schacht E, Bruyere O, Ethgen O, Gourlay M, Reginster JY. Vitamin D analogs versus native vitamin D in preventing bone loss and osteoporosis-related fractures: a comparative meta-analysis. Calcified Tissue Int. 2005;76:176-86.
31 Shaukat A, Scouras N, Schunemann HJ. Role of supplemental calcium in the recurrence of colorectal adenomas: a metaanalysis of randomized controlled trials. Am J Gastroenterol. 2005;100:390-4. [pmid: 15667497].
32 Dagnelie PC, Schuurman AG, Goldbohm RA, van den Brandt PA. Diet, anthropometric measures and prostate cancer risk: a review of prospective cohort and intervention studies. BJU Int. 2004;93:1139-50. [pmid: 15142129].
33 Bischoff-Ferrari HA, wson-Hughes B, Willett WC, et al. Effect of Vitamin D on falls: a meta-analysis. JAMA. 2004;291:1999-2006. [pmid: 15113819].
34 Richy F, Ethgen O, Bruyere O, Reginster JY. Efficacy of alphacalcidol and calcitriol in primary and corticosteroid-induced osteoporosis: a meta-analysis of their effects on bone mineral density and fracture rate. Osteoporosis Int. 2004;15:301-10.
35 Xu L, McElduff P, D'Este C, Attia J. Does dietary calcium have a protective effect on bone fractures in women? A meta-analysis of observational studies. Br J Nutr. 2004;91:625-34. [pmid: 15035690].
36 Latham NK, Anderson CS, Reid IR. Effects of vitamin D supplementation on strength, physical performance, and falls in older persons: a systematic review. J Am Geriatr Soc. 2003;51:1219-26. [pmid: 12919233].
37 Hofmeyr GJ, Roodt A, Atallah AN, Duley L. Calcium supplementation to prevent preeclampsia-- a systematic review. SAMJ-South African Medical Journal. Suid-Afrikaanse. 2003:224-8.
38 Meunier PJ. Evidence-based medicine and osteoporosis: a comparison of fracture risk reduction data from osteoporosis randomised clinical trials. Int J Clin Pract. 1999;53:122-9. [pmid: 10344048].
39 Papadimitropoulos E, Wells G, Shea B, et al. Meta-analyses of therapies for postmenopausal osteoporosis. VIII: Meta-analysis of the efficacy of vitamin D treatment in preventing osteoporosis in postmenopausal women. Endocr Rev. 2002;23:560-9. [pmid: 12202471].
40 Shea B, Wells G, Cranney A, et al. Meta-analyses of therapies for postmenopausal osteoporosis. VII. Meta-analysis of calcium supplementation for the prevention of postmenopausal osteoporosis. Endoc Rev. 2002;23:552-9.
41 Amin S, LaValley MP, Simms RW, Felson DT. The role of vitamin D in corticosteroid-induced osteoporosis: a meta-analytic approach. Arthritis & Rheumatism. 1999;42:1740-51. [pmid: 10446876].
42 Cumming RG, Nevitt MC. Calcium for prevention of osteoporotic fractures in postmenopausal women. J Bone Miner Res. 1997;12:1321-9. [pmid: 9286747].
43 Bergsma-Kadijk JA, van ' V, Kampman E, Burema J. Calcium does not protect against colorectal neoplasia. Epidemiol. 1996;7:590-7.
44 Allender PS, Cutler JA, Follmann D, Cappuccio FP, Pryer J, Elliott P. Dietary calcium and blood pressure: a meta-analysis of randomized clinical trials. Ann Intern Med. 1996;124:825-31. [pmid: 8610952].
45 Bucher HC, Cook RJ, Guyatt GH, et al. Effects of dietary calcium supplementation on blood pressure. A meta-analysis of randomized controlled trials. JAMA. 1996;275:1016-22. [pmid: 8596234].
46 Welten DC, Kemper HC, Post GB, van Staveren WA. A meta-analysis of the effect of calcium intake on bone mass in young and middle aged females and males. J Nutr. 1995;125:2802-13. [pmid: 7472660].
47 Cappuccio FP, Elliott P, Allender PS, Pryer J, Follman DA, Cutler JA. Epidemiologic association between dietary calcium intake and blood pressure: a meta-analysis of published data. Am J Epidemiol. 1995;142:935-45. [pmid: 7572974].
48 Carroli G, Duley L, Belizan JM, Villar J. Calcium supplementation during pregnancy: a systematic review of randomised controlled trials. Br J Obstet Gynecol. 1994;101:753-8.
49 Cumming RG. Calcium intake and bone mass: a quantitative review of the evidence 2446. Calcified Tissue Int. 1990;47:194-201.
50 Mackerras D, Lumley T. First- and second-year effects in trials of calcium supplementation on the loss of bone density in postmenopausal women. Bone. 1997;21:527-33. [pmid: 9430243].
51 Cappuccio FP, Siani A, Strazzullo P. Oral calcium supplementation and blood pressure: an overview of randomized controlled trials. J Hyperten. 1989;7:941-6.
52 Bjelakovic G, Nikolova D, Gluud LL, Simonetti RG, Gluud C. Mortality in randomized trials of antioxidant supplements for primary and secondary prevention: systematic review and meta-analysis. JAMA. 2007;297:842-57. [pmid: 17327526].
53 Bjelakovic G, Nagorni A, Nikolova D, Simonetti RG, Bjelakovic M, Gluud C. Meta-analysis: antioxidant supplements for primary and secondary prevention of colorectal adenoma. Aliment Pharmacol Therapeut. 2006;24:281-91.
54 Garcia-Closas R, Castellsague X, Bosch X, Gonzalez CA. The role of diet and nutrition in cervical carcinogenesis: a review of recent evidence. Int J Cancer. 2005;117:629-37. [pmid: 15912536].
55 Etminan M, Gill SS, Samii A. Intake of vitamin E, vitamin C, and carotenoids and the risk of Parkinson's disease: a meta-analysis. Lancet Neurol. 2005;4:362-5. [pmid: 15907740].
56 Bjelakovic G, Nikolova D, Simonetti RG, Gluud C. Antioxidant supplements for prevention of gastrointestinal cancers: a systematic review and meta-analysis. Lancet. 2004;364:1219-28. [pmid: 15464182].
57 Ramakrishnan U, Aburto N, McCabe G, Martorell R. Multimicronutrient interventions but not vitamin a or iron interventions alone improve child growth: results of 3 meta-analyses. J Nutr. 2004;134:2592-602. [pmid: 15465753].
58 Myhre AM, Carlsen MH, Bohn SK, Wold HL, Laake P, Blomhoff R. Water-miscible, emulsified, and solid forms of retinol supplements are more toxic than oil-based preparations. Am J Clin Nutr. 2003;78:1152-9. [pmid: 14668278].
59 Gray M. Does oral supplementation with vitamins A or E promote healing of chronic wounds?. J Wound Ostomy Continence Nurs. 2003;30:290-4. [pmid: 14615755].
60 Morris CD, Carson S. Routine vitamin supplementation to prevent cardiovascular disease: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2003;139:56-70. [pmid: 12834320].
61 Vivekananthan DP, Penn MS, Sapp SK, Hsu A, Topol EJ. Use of antioxidant vitamins for the prevention of cardiovascular disease: meta-analysis of randomised trials. Lancet. 2003;361:2017-23. [pmid: 12814711].
62 Grotto I, Mimouni M, Gdalevich M, Mimouni D. Vitamin A supplementation and childhood morbidity from diarrhea and respiratory infections: a meta-analysis. J Pediatr. 2003;142:297-304. [pmid: 12640379].
63 Gupta P, Indrayan A. Effect of vitamin A supplementation on childhood morbidity and mortality: critical review of Indian studies. Indian Pediatr. 2002;39:1099-118. [pmid: 12522272].
64 D'Souza RM, D'Souza R. Vitamin A for the treatment of children with measles--a systematic review. J Tropical Pediatr. 2002;48:323-7.
65 D'Souza RM, D'Souza R. Vitamin A for preventing secondary infections in children with measles--a systematic review. J Tropical Pediatr. 2002;48:72-7.
66 Asplund K. Antioxidant vitamins in the prevention of cardiovascular disease: a systematic review. J Intern Med. 2002;251:372-92. [pmid: 11982737].
67 Sloan NL, Jordan E, Winikoff B. Effects of iron supplementation on maternal hematologic status in pregnancy. Am J Public Health. 2002;92:288-93. [pmid: 11818308].
68 Steinmaus CM, Nunez S, Smith AH. Diet and bladder cancer: a meta-analysis of six dietary variables 1845. Am J Epidemiol. 2000;151:693-702. [pmid: 10752797].
69 Gandini S, Merzenich H, Robertson C, Boyle P. Meta-analysis of studies on breast cancer risk and diet: the role of fruit and vegetable consumption and the intake of associated micronutrients. Eur J Cancer. 2000;36:636-46. [pmid: 10738129].
70 Marchioli R. Antioxidant vitamins and prevention of cardiovascular disease: laboratory, epidemiological and clinical trial data. Pharmacol Research. 1999;40:227-38.
71 Law MR, Morris JK. By how much does fruit and vegetable consumption reduce the risk of ischaemic heart disease?. Eur J Clin Nutr. 1998;52:549-56. [pmid: 9725654].
72 Lonn EM, Yusuf S. Is there a role for antioxidant vitamins in the prevention of cardiovascular diseases? An update on epidemiological and clinical trials data. Can J Cardiol. 1997;13:957-65. [pmid: 9374952].
73 Giles G, Ireland P. Diet, nutrition and prostate cancer. Int J Cancer. 1997;(Suppl):10-7.
74 Glasziou PP, Mackerras DE. Vitamin A supplementation in infectious diseases: a meta-analysis. BMJ. 1993;306:366-70. [pmid: 8461682].
75 Fawzi WW, Chalmers TC, Herrera MG, Mosteller F. Vitamin A supplementation and child mortality. A meta-analysis. JAMA. 1993;269:898-903. [pmid: 8426449].
76 Aminbakhsh A, Mancini J. Chronic antioxidant use and changes in endothelial dysfunction: a review of clinical investigations. Can J Cardiol. 1999;15:895-903. [pmid: 10446437].
77 Polyzos NP, Mauri D, Tsappi M, et al. Combined vitamin C and E supplementation during pregnancy for preeclampsia prevention: a systematic review. Obstet Gynecol Survey. 2007;62:202-6.
78 Coulter ID, Hardy ML, Morton SC, et al. Antioxidants vitamin C and vitamin e for the prevention and treatment of cancer. J Gen Intern Med. 2006;21:735-44. [pmid: 16808775].
79 Pham DQ, Plakogiannis R. Vitamin E supplementation in Alzheimer's disease, Parkinson's disease, tardive dyskinesia, and cataract: Part 2. Ann Pharmacotherapy. 2005;39:2065-72.
80 Pham DQ, Plakogiannis R. Vitamin E supplementation in cardiovascular disease and cancer prevention: Part 1. Ann Pharmacotherapy. 2005;39:1870-8.
81 Alkhenizan AH, Al-Omran MA. The role of vitamin E in the prevention of coronary events and stroke. Meta-analysis of randomized controlled trials. Saudi Med J. 2004;25:1808-14. [pmid: 15711645].
82 Eidelman RS, Hollar D, Hebert PR, Lamas GA, Hennekens CH. Randomized trials of vitamin E in the treatment and prevention of cardiovascular disease. Arch Intern Med. 2004;164:1552-6. [pmid: 15277288].
83 Shekelle PG, Morton SC, Jungvig LK, et al. Effect of supplemental vitamin E for the prevention and treatment of cardiovascular disease. J Gen Intern Med. 2004;19:380-9. [pmid: 15061748].
84 Lacour M, Zunder T, Restle A, Schwarzer G. No evidence for an impact of selenium supplementation on environment associated health disorders--a systematic review. Int J Hyg Environ Health. 2004;207:1-13. [pmid: 14762969].
85 Bleys J, Miller ER III, Pastor-Barriuso R, Appel LJ, Guallar E. Vitamin-mineral supplementation and the progression of atherosclerosis: a meta-analysis of randomized controlled trials. Am J Clin Nutr. 954;84:880-7.
86 Yeh GY, Eisenberg DM, Kaptchuk TJ, Phillips RS. Systematic review of herbs and dietary supplements for glycemic control in diabetes. Diabetes Care. 2003;26:1277-94. [pmid: 12663610].
87 Moreira A, Kekkonen RA, Delgado L, Fonseca J, Korpela R, Haahtela T. Nutritional modulation of exercise-induced immunodepression in athletes: a systematic review and meta-analysis. Eur J Clin Nutr. 2007;61:443-60. [pmid: 17136044].
88 Barak Y, Swartz M, Shamir E, Stein D, Weizman A. Vitamin E (alpha-tocopherol) in the treatment of tardive dyskinesia: a statistical meta-analysis. Ann Clin Psychiatr. 1998;10:101-5.
89 Raju TN, Langenberg P, Bhutani V, Quinn GE. Vitamin E prophylaxis to reduce retinopathy of prematurity: a reappraisal of published trials. J Pediatr. 1997;131:844-50. [pmid: 9427888].
90 Hemila H. Vitamin C supplementation and respiratory infections: a systematic review. Military Med. 2004;169:920-5.
91 Ness AR, Chee D, Elliott P. Vitamin C and blood pressure--an overview. J Hum Hyperten. 1997;11:343-50.
92 Hemila H. Vitamin C intake and susceptibility to the common cold. Br J Nutr. 1997;77:59-72. [pmid: 9059230].
93 Ness AR, Powles JW, Khaw KT. Vitamin C and cardiovascular disease: a systematic review. J Cardiovascular Risk. 1996;3:513-21.
94 Muggli EE, Halliday JL. Folic acid and risk of twinning: a systematic review of the recent literature, July 1994 to July 2006. Med J Aust. 2007;186:243-8. [pmid: 17391087].
95 Badovinac RL, Werler MM, Williams PL, Kelsey KT, Hayes C. Folic acid-containing supplement consumption during pregnancy and risk for oral clefts: a meta-analysis. Birth Defects Research. 2007;79:8-15. [pmid: 17133404].
96 Larsson SC, Giovannucci E, Wolk A. Folate and risk of breast cancer: a meta-analysis. J Natl Cancer Inst. 2007;99:64-76. [pmid: 17202114].
97 Balk EM, Raman G, Tatsioni A, Chung M, Lau J, Rosenberg IH. Vitamin B6, B12, and folic acid supplementation and cognitive function: a systematic review of randomized trials. Arch Intern Med. 2007;167:21-30. [pmid: 17210874].
98 Bazzano LA, Reynolds K, Holder KN, He J. Effect of folic acid supplementation on risk of cardiovascular diseases: a meta-analysis of randomized controlled trials. JAMA. 2006;296:2720-6. [pmid: 17164458].
99 Lewis SJ, Harbord RM, Harris R, Smith GD. Meta-analyses of observational and genetic association studies of folate intakes or levels and breast cancer risk. J Natl Cancer Inst. 2006;98:1607-22. [pmid: 17105984].
100 Larsson SC, Giovannucci E, Wolk A. Folate intake, MTHFR polymorphisms, and risk of esophageal, gastric, and pancreatic cancer: a meta-analysis. Gastroenterol. 2006;131:1271-83.
101 Homocysteine Lowering TC. Dose-dependent effects of folic acid on blood concentrations of homocysteine: a meta-analysis of the randomized trials. Am J Clin Nutr. 2005;82:806-12. [pmid: 16210710].
102 Sanjoaquin MA, Allen N, Couto E, Roddam AW, Key TJ. Folate intake and colorectal cancer risk: a meta-analytical approach. International Journal of Cancer. 2005;113:825-8.
103 Taylor MJ, Carney SM, Goodwin GM, Geddes JR. Folate for depressive disorders: systematic review and meta-analysis of randomized controlled trials. J Psychopharmacol. 2004;18:251-6. [pmid: 15260915].
104 Ellinson M, Thomas J, Patterson A. A critical evaluation of the relationship between serum vitamin B, folate and total homocysteine with cognitive impairment in the elderly. J Hum Nutr Dietet. 385;17:371-83.
105 de BA, Mennen LI, Hercberg S, Galan P. Evidence for a protective (synergistic?) effect of B-vitamins and omega-3 fatty acids on cardiovascular diseases. Eur J Clin Nutr. 2004;58:732-44. [pmid: 15116076].
106 Diculescu M, Ciocirlan M, Ciocirlan M, et al. Folic acid and sulfasalazine for colorectal carcinoma chemoprevention in patients with ulcerative colitis: the old and new evidence. Romanian J Gastroenterol. 2003;12:283-6.
107 Ray JG, Laskin CA. Folic acid and homocyst(e)ine metabolic defects and the risk of placental abruption, pre-eclampsia and spontaneous pregnancy loss: A systematic review. Placenta. 1999;20:519-29. [pmid: 10452905].
108 Lowering blood homocysteine with folic acid based supplements: meta-analysis of randomised trials. Homocysteine Lowering Trialists' Collaboration. BMJ. 1998;316:894-8. [pmid: 9569395].
109 Boushey CJ, Beresford SA, Omenn GS, Motulsky AG. A quantitative assessment of plasma homocysteine as a risk factor for vascular disease. Probable benefits of increasing folic acid intakes. JAMA. 1995;274:1049-57. [pmid: 7563456].
110 Periodic health examination, 1994 update: 3. Primary and secondary prevention of neural tube defects. Canadian Task Force on the Periodic Health Examination. CMAJ Canadian Medical Association Journal. 1994;151:159-66.
111 Gorham ED, Garland CF, Garland FC, et al. Optimal vitamin D status for colorectal cancer prevention: a quantitative meta analysis. Am J Prev Med. 2007;32:210-6. [pmid: 17296473].
112 Gorham ED, Garland CF, Garland FC, et al. Vitamin D and prevention of colorectal cancer. J Steroid Biochem Mol Biol. 2005;97:179-94. [pmid: 16236494].
113 Grant WB, Garland CF. A critical review of studies on vitamin D in relation to colorectal cancer. Nutr Cancer. 2004;48:115-23. [pmid: 15231446].
114 Weatherall M. A meta-analysis of 25 hydroxyvitamin D in older people with fracture of the proximal femur. NZ Med J. 2000;113:137-40.
115 Sun Y, Lai MS, Lu CJ. Effectiveness of vitamin B12 on diabetic neuropathy: systematic review of clinical controlled trials. Acta Neurologica Taiwanica. 2005;14:48-54. [pmid: 16008162].
116 Butler CC, Vidal-Alaball J, Cannings-John R, et al. Oral vitamin B12 versus intramuscular vitamin B12 for vitamin B12 deficiency: a systematic review of randomized controlled trials. Family Practice. 2006;23:279-85. [pmid: 16585128].
117 Ray JG, Blom HJ. Vitamin B12 insufficiency and the risk of fetal neural tube defects. Qjm. 2003;96:289-95. [pmid: 12651973].
118 Brinkman M, Reulen RC, Kellen E, Buntinx F, Zeegers MP. Are men with low selenium levels at increased risk of prostate cancer?. Eur J Cancer. 2006;42:2463-71. [pmid: 16945521].
119 Flores-Mateo G, Navas-Acien A, Pastor-Barriuso R, Guallar E. Selenium and coronary heart disease: a meta-analysis. Am J Clin Nutr. 2006;84:762-73. [pmid: 17023702].
120 Etminan M, FitzGerald JM, Gleave M, Chambers K. Intake of selenium in the prevention of prostate cancer: a systematic review and meta-analysis. Cancer Causes Control. 2005;16:1125-31. [pmid: 16184479].
121 Zhuo H, Smith AH, Steinmaus C. Selenium and lung cancer: a quantitative analysis of heterogeneity in the current epidemiological literature. Cancer Epidemiol Biomarkers Prev. 2004;13:771-8. [pmid: 15159309].
122 He FJ, MacGregor GA. Importance of salt in determining blood pressure in children: meta-analysis of controlled trials. Hypertension. 2006;48:861-9. [pmid: 17000923].
123 Jones-Burton C, Mishra SI, Fink JC, et al. An in-depth review of the evidence linking dietary salt intake and progression of chronic kidney disease. Am J Nephrol. 2006;26:268-75. [pmid: 16763384].
124 Geleijnse JM, Kok FJ, Grobbee DE. Blood pressure response to changes in sodium and potassium intake: a metaregression analysis of randomised trials. J Hum Hyperten. 2003;17:471-80.
125 He FJ, MacGregor GA. Effect of modest salt reduction on blood pressure: a meta-analysis of randomized trials. Implications for public health. J Hum Hyperten. 2002;16:761-70.
126 Hooper L, Bartlett C, Davey SG, Ebrahim S. Systematic review of long term effects of advice to reduce dietary salt in adults. BMJ. 2002;325:628. [pmid: 12242173].
127 Graudal NA, Galloe AM, Garred P. Effects of sodium restriction on blood pressure, renin, aldosterone, catecholamines, cholesterols, and triglyceride: a meta-analysis. JAMA. 1998;279:1383-91. [pmid: 9582047].
128 Midgley JP, Matthew AG, Greenwood CM, Logan AG. Effect of reduced dietary sodium on blood pressure: a meta-analysis of randomized controlled trials. JAMA. 1996;275:1590-7. [pmid: 8622251].
129 Cutler JA, Follmann D, Elliott P, Suh I. An overview of randomized trials of sodium reduction and blood pressure. Hypertension. 1991;17(Suppl-33).
130 Alam S, Johnson AG. A meta-analysis of randomised controlled trials (RCT) among healthy normotensive and essential hypertensive elderly patients to determine the effect of high salt (NaCl) diet of blood pressure. J Hum Hyperten. 1999;13:367-74.
131 Ebrahim S, Smith GD. Lowering blood pressure: a systematic review of sustained effects of non-pharmacological interventions. J Public Health Med. 1998;20:441-8. [pmid: 9923952].
132 Wyatt KM, Dimmock PW, Jones PW, Shaughn O'Brien PM. Efficacy of vitamin B-6 in the treatment of premenstrual syndrome: systematic review. BMJ. 1999;318:1375-81. [pmid: 10334745].
133 Gera T, Sachdev HP, Nestel P, Sachdev SS. Effect of iron supplementation on haemoglobin response in children: systematic review of randomised controlled trials. J Pediatr Gastroenterol Nutr. 2007;44:468-86. [pmid: 17414146].
134 Gera T, Sachdev HP, Nestel P. Effect of iron supplementation on physical performance in children and adolescents: systematic review of randomized controlled trials. Indian Pediatrics. 2007;44:15-24. [pmid: 17277426].
135 Sachdev H, Gera T, Nestel P. Effect of iron supplementation on physical growth in children: systematic review of randomised controlled trials. Public Health Nutr. 2006;9:904-20. [pmid: 17010257].
136 Iannotti LL, Tielsch JM, Black MM, Black RE. Iron supplementation in early childhood: health benefits and risks. Am J Clin Nutr. 2006;84:1261-76. [pmid: 17158406].
137 Sachdev H, Gera T, Nestel P. Effect of iron supplementation on mental and motor development in children: systematic review of randomised controlled trials. Public Health Nutr. 2005;8:117-32. [pmid: 15877905].
138 Gera T, Sachdev HP. Effect of iron supplementation on incidence of infectious illness in children: systematic review. BMJ. 2002;325:1142. [pmid: 12433763].
139 Tran T, Wax JR, Philput C, Steinfeld JD, Ingardia CJ. Intentional iron overdose in pregnancy--management and outcome. J Emerg Med. 2000;18:225-8. [pmid: 10699527].
140 Gray M. Does oral zinc supplementation promote healing of chronic wounds?. J Wound Ostomy Continence Nurs. 2003;30:295-9. [pmid: 14615757].
141 Brown KH, Peerson JM, Rivera J, Allen LH. Effect of supplemental zinc on the growth and serum zinc concentrations of prepubertal children: a meta-analysis of randomized controlled trials. Am J Clin Nutr. 2002;75:1062-71. [pmid: 12036814].
142 Song Y, He K, Levitan EB, Manson JE, Liu S. Effects of oral magnesium supplementation on glycaemic control in Type 2 diabetes: a meta-analysis of randomized double-blind controlled trials. Diabetic Med. 2006;23:1050-6. [pmid: 16978367].
143 Miller S, Crystal E, Garfinkle M, Lau C, Lashevsky I, Connolly SJ. Effects of magnesium on atrial fibrillation after cardiac surgery: a meta-analysis. Heart. 2005;91:618-23. [pmid: 15831645].
144 Jee SH, Miller ER III, Guallar E, Singh VK, Appel LJ, Klag MJ. The effect of magnesium supplementation on blood pressure: a meta-analysis of randomized clinical trials. Am J Hyperten. 2002;15:691-6.
145 Mizushima S, Cappuccio FP, Nichols R, Elliott P. Dietary magnesium intake and blood pressure: a qualitative overview of the observational studies. J Hum Hyperten. 1998;12:447-53.
146 Pittler MH, Stevinson C, Ernst E. Chromium picolinate for reducing body weight: meta-analysis of randomized trials. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 2003;27:522-9. [pmid: 12664086].
147 Nissen SL, Sharp RL. Effect of dietary supplements on lean mass and strength gains with resistance exercise: a meta-analysis. J Appl Physiol. 2003;94:651-9. [pmid: 12433852].
148 Althuis MD, Jordan NE, Ludington EA, Wittes JT. Glucose and insulin responses to dietary chromium supplements: a meta-analysis. Am J Clin Nutr. 2002;76:148-55. [pmid: 12081828].
149 Goh YI, Bollano E, Einarson TR, Koren G. Prenatal multivitamin supplementation and rates of pediatric cancers: a meta-analysis. Clin Pharmacol Therapeutics. 2007;81:685-91.
150 Stephen AI, Avenell A. A systematic review of multivitamin and multimineral supplementation for infection. J Hum Nutr Diet. 2006;19:179-90. [pmid: 16756533].
151 Huang HY, Caballero B, Chang S, et al. The efficacy and safety of multivitamin and mineral supplement use to prevent cancer and chronic disease in adults: a systematic review for a National Institutes of Health state-of-the-science conference. Ann Intern Med. 2006;145:372-85. [pmid: 16880453].
152 Goh YI, Bollano E, Einarson TR, Koren G. Prenatal multivitamin supplementation and rates of congenital anomalies: a meta-analysis. J Obstetr Gynaecol Can: JOGC. 2006;28:680-9.
153 El-Kadiki A, Sutton AJ. Role of multivitamins and mineral supplements in preventing infections in elderly people: systematic review and meta-analysis of randomised controlled trials. BMJ. 2005;330:871. [pmid: 15805125].
154 Whelton PK, He J, Cutler JA, et al. Effects of oral potassium on blood pressure. Meta-analysis of randomized controlled clinical trials. JAMA. 1997;277:1624-32. [pmid: 9168293].
155 Cappuccio FP, MacGregor GA. Does potassium supplementation lower blood pressure? A meta-analysis of published trials. J Hyperten. 1991;9:465-73.
156 Cockayne S, Adamson J, Lanham-New S, Shearer MJ, Gilbody S, Torgerson DJ. Vitamin K and the prevention of fractures: systematic review and meta-analysis of randomized controlled trials. Arch Intern Med. 2006;166:1256-61. [pmid: 16801507].
157 Brousson MA, Klein MC. Controversies surrounding the administration of vitamin K to newborns: a review. CMAJ Canadian Medical Association Journal. 1996;154:307-15.
158 Ismail AI, Bandekar RR. Fluoride supplements and fluorosis: a meta-analysis. Community Dent Oral Epidemiol. 1999;27:48-56. [pmid: 10086926].
159 Kotwal A, Priya R, Qadeer I. Goiter and other iodine deficiency disorders: A systematic review of epidemiological studies to deconstruct the complex web. Arch Med Research. 2007;38:1-14. [pmid: 17174717].
160 Clar C, Wu T, Liu G, Li P. Iodized salt for iodine deficiency disorders. A systematic review. Endocrinol Metab Clin North Am. 2002;31:681-98. [pmid: 12227127].
161 Gonzalez-Reyes RE, Gutierrez-Alvarez AM, Moreno CB. Manganese and epilepsy: a systematic review of the literature. Brain Research Rev. 2007;53:332-6. [pmid: 17166592].
162 Myers VH, Champagne CM. Nutritional effects on blood pressure. Curr Opin Lipidol. 2007;18:20-4. [pmid: 17218827].
163 Dennehy CE. The use of herbs and dietary supplements in gynecology: an evidence-based review. J Midwifery Womens Health. 2006;51:402-9. [pmid: 17081929].
164 Trumbo PR, Ellwood KC. Chromium picolinate intake and risk of type 2 diabetes: an evidence-based review by the United States Food and Drug Administration. Nutr Rev. 2006;64:357-63. [pmid: 16958312].
165 Thacher TD, Fischer PR, Strand MA, Pettifor JM. Nutritional rickets around the world: causes and future directions. Ann Trop Paeditatr. 2006;26:1-16.
166 Rios J, Passe MM. Evidenced-based use of botanicals, minerals, and vitamins in the prophylactic treatment of migraines. J Am Acad Nurse Pract. 2004;16:251-6. [pmid: 15264611].
167 Zeegers MP, Kellen E, Buntinx F, van den Brandt PA. The association between smoking, beverage consumption, diet and bladder cancer: a systematic literature review. World J Urol. 2004;21:392-401. [pmid: 14685762].
168 Dickey RA, Janick JJ. Lifestyle modifications in the prevention and treatment of hypertension. Endocr Pract. 2001;7:392-9. [pmid: 11585378].
169 Kraemer K, Koch W, Hoppe PP. Is all-rac-alpha-tocopherol different from RRR-alpha-tocopherol regarding cardiovascular efficacy? A meta-analysis of clinical trials. Ann NY Acad Sci. 2004;1031:435-8. [pmid: 15753190].
170 Potential interventions for the prevention of childhood pneumonia in developing countries: a meta-analysis of data from field trials to assess the impact of vitamin A supplementation on pneumonia morbidity and mortality. The Vitamin A and Pneumonia Working Group. Bulletin of the World Health Organization. 1995;73:609-19. [pmid: 8846487].
171 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17:1-12. [pmid: 8721797].
172 Schulz KF, Chalmers I, Hayes RJ, Altman DG. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273:408-12. [pmid: 7823387].
173 Marantz PR, Bird ED, Alderman MH. A call for higher standards of evidence for dietary guidelines. Am J Prev Med. 2008;34:234-40. [pmid: 18312812].
174 Whitlock EP, Lin JS, Chou R, Shekelle P, Robinson KA. Using Existing Systematic Reviews in Complex Systematic Reviews. Ann Intern Med. 2008;148:776-82. [pmid: 18490690].
175 McAuley L, Pham B, Tugwell P, Moher D. Does the inclusion of grey literature influence estimates of intervention effectiveness reported in meta-analyses?. Lancet. 2000;356:1228-31. [pmid: 11072941].
176 Dickersin K, Rennie D. Registering clinical trials. JAMA. 2003;290:516-23. [pmid: 12876095].
177 Lau J, Ioannidis JP, Terrin N, Schmid CH, Olkin I. The case of the misleading funnel plot. BMJ. 2006;333:597-600. [pmid: 16974018].
178 Terrin N, Schmid CH, Lau J. In an empirical evaluation of the funnel plot, researchers could not visually identify publication bias. J Clin Epidemiol. 2005;58:894-901. [pmid: 16085192].
179 Pham B, Platt R, McAuley L, Klassen TP, Moher D. Is there a "best" way to detect and minimize publication bias? An empirical evaluation. Eval Health Prof. 2001;24:109-25. [pmid: 11523382].
180 Moher D, Schulz KF, Altman DG. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomised trials. Clin Oral Investig. 2003;7:2-7.
181 Gagnier JJ, Boon H, Rochon P, Moher D, Barnes J, Bombardier C. Reporting randomized, controlled trials of herbal interventions: an elaborated CONSORT statement. Ann Intern Med. 2006;144:364-7. [pmid: 16520478].
182 von EE, Altman DG, Egger M, Pocock SJ, Gotzsche PC, Vandenbroucke JP. The Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) statement: guidelines for reporting observational studies. Lancet. 2007;370:1453-7. [pmid: 18064739].
183 Delaney A, Bagshaw SM, Ferland A, Manns B, Laupland KB, Doig CJ. A systematic evaluation of the quality of meta-analyses in the critical care literature 3267. Crit Care. 2005;9:R575-R582. [pmid: 16277721].