# List of Acronyms/Abbreviations

ADA: American Dietetic Association
AHRQ: Agency for Healthcare Research and Quality
CONSORT: Consolidated Standard of Reporting Trials
FDA: Food and Drug Administration
IQR: Interquartile range
MOOSE: Meta-analysis of Observational Studies in Epidemiology
NIH: National Institutes of Health
ODS: Office for Dietary Supplements
PICO: Population, Intervention (or exposure), Comparator, Outcome
QUOROM: Quality of Reporting of Meta-analysis
SR: Systematic Review
STROBE: Strengthening the Reporting of Observational Studies in Epidemiology
USPSTF: United States Preventive Services Task Force