# Methods

## Literature Search

We searched MEDLINE® from its inception through July 2007 using keywords for micronutrients, multivitamins, and antioxidants. We also searched for SRs, evidence-based reviews and meta-analyses (Supplementary Table). Citations of SRs were reviewed for additional relevant articles. The essential micronutrients included in the analysis were fat-soluble vitamins A, D, E, and K; water-soluble vitamins B (thiamin, riboflavin, niacin, pantothenic acid, pyridoxine, biotin, folate, B12) and C; macrominerals (calcium, chloride, magnesium, phosphorous, potassium, sodium and sulfur); and trace minerals (chromium, copper, fluoride, iodide, iron, manganese, molybdenum, selenium, and zinc). Multivitamins or minerals and antioxidant supplements were also included. Potentially relevant reviews included those whose abstracts described searches or eligibility criteria for study identification, or included terms such as “systematic,” “evidence,” “evidence-based,” “meta-analysis,” or “pooled analysis.”

## Eligibility Criteria

Full-text articles of screened-in abstracts were retrieved and examined to confirm their eligibility according to predetermined criteria. For the purpose of this study, we defined a SR as a study that contained three components: a statement of the research questions (aims or objectives); a description of the literature search; and a listing of the study eligibility criteria. A review that lacked any of these components was excluded. We did not attempt to contact authors for clarification. The following types of reviews were excluded: reviews of foods or diets that did not quantify micronutrient intake, reviews including non-oral routes of nutrient delivery, reviews that did not relate nutrients to health outcomes, reviews of non-human data, and pooled analyses of primary databases (i.e., secondary database analyses of multiple cohorts) that did not include a SR.

## Data Abstraction and Collection

The unit of analysis was the SR article. We did not analyze the primary studies within the SRs. The following data were collected from the full-text articles of eligible SRs: topics covered (exposures and outcomes), whether meta-analyses were performed, specific journal, publication date, and number of citations per SR. We categorized the outcomes examined as either clinical outcomes or intermediate outcomes. A clinical outcome was defined as a measurement of how a person feels, functions or survives, or the severity of an existing disease, or the incidence of a new diagnosis. Intermediate disease outcomes included laboratory measurements or physical signs used as surrogates for a clinical endpoint (e.g., plasma cholesterol concentrations or blood pressure for cardiovascular disease, or dark adaptation for night blindness).

A standardized form was used for data collection. From published guidelines for reporting of the meta-analyses such as MOOSE (9) and QUOROM (10), we collected and evaluated 28 reporting items regarding the search and study selection criteria; methods for assessing methodological quality of the included primary studies, methods for quantitative syntheses, and protocols for reporting of results. The primary goal of guidelines for SR reporting is to encourage authors to provide clear and transparent reporting of the factors relating to the literature review and evidence syntheses they carried out. Most widely recognized reporting guidelines reflect consensus opinion of groups of experts in a particular field, including research methodologists and journal editors (13). Because there is no widely accepted guidance for reporting or analyses of variables unique to the field of nutrition in SRs, we included seven items in addition to those identified in MOOSE and QUOROM specific to nutrition or diet variables based on the concern that failure to adhere to the items could lead to biased syntheses and/or interpretation of results in nutrition-related SRs. The definitions and the reasons for selecting these 35 reporting items are described in Table 1.

Table 1 Reporting items for nutrition-related systematic reviews (with or without meta-analyses)

Reporting Item | Definition for Adequate Reporting | Rationale for Inclusion
Search terms | Keywords for identifying relevant studies for the research questions (i.e., PI(E)COS), or complete search strategy (e.g., keywords, medical subject headings) were described or referred to elsewhere. | In QUOROM and MOOSE
Searches in multiple databases | Search was conducted in more than one electronic database. | In QUOROM and MOOSE
Search years | Time period of the articles searched and included was described. | In QUOROM and MOOSE
Searches in multiple languages | Search was conducted in English and other languages. | In QUOROM and MOOSE
Searching for unpublished data | Authors explicitly stated the efforts to include unpublished data (e.g., contact with authors, meeting abstracts or conference preceding, dissertations, or grey literature search). | In QUOROM and MOOSE
Inclusion or exclusion criteria | Definitions of at least two of the PI(E)COS criteria (e.g., randomized controlled trials of the vitamin E were included) were reported. | In QUOROM and MOOSE
Baseline nutrition status of the population | Nutrition status of the population at baseline (i.e., malnutrition, normal, or mixed). Acceptable data include data from nutrition assessments, explicit interpretations or discussions of the nutrition status of the locations where the study were conducted, and inclusion/exclusion criterion for the nutrition status of the study population. | Malnutrition is associated with vitamins and/or mineral deficiencies. Under- or over-nutrition is associated with mechanisms that affect health outcomes (14). Therefore, baseline nutrition status is an important covariate in any studies concerning the associations between micronutrients and health.
Types of interventions/exposures | Nutrient interventions or exposures were described (must include dose/level and type). | In QUOROM and MOOSE
Types of comparators | Comparators were described (must include dose/level and type). | In QUOROM and MOOSE
Types of outcomes | Outcomes or endpoints were defined. | In QUOROM and MOOSE
Types of study designs | Design of the included studies was described. | In QUOROM
Number of included and excluded studies | Number of eligible and ineligible studies identified from the search was reported. | In QUOROM
Reasons for exclusion | Reasons for exclusions were described. | In QUOROM and MOOSE
Use of specific checklist for quality items | The list of quality items for the validity (or quality) assessment of studies were applied and reported for each included study | In QUOROM and MOOSE
Overall rating of the study given | A overall rating of study quality was assessed (e.g. A, B, C or Good, Fair, Poor) | In QUOROM and MOOSE
Models for meta- analyses^*^ | The methods of combining estimates (e.g., fixed- and random-effects models) were reported. | In QUOROM and MOOSE
Assessment for heterogeneity | Heterogeneity across studies was assessed (i.e., statistical methods) or discussed (i.e., qualitative analyses). | In QUOROM and MOOSE
Dose-response relationship of the nutrient-outcome associations/effects | Dose-response relationships were examined using dose-response statistical models, meta-regression, or subgroup analyses by different doses (i.e., quantitative assessments), or examined qualitatively (i.e. discussions). | In MOOSE
Assessment of publication bias | Quantitative assessment of publication bias (e.g., funnel plot, Begg and Egger tests) was used. | In QUOROM and MOOSE
Discussion of publication bias | Issue of publication bias was raised in Discussion. | In MOOSE
Data sufficient to calculate the effect size^*^ | Data needed to calculate the effect size (e.g., 2×2 table, or mean change within group) for each study were presented in the tables or figures. | In QUOROM and MOOSE
Flow diagram for the number of included and excluded studies | A flow diagram showing the progress of study selection was presented. | In QUOROM
The total number of primary studies included in the systematic review/meta-analysis | The total number of studies that met inclusion criteria was reported in the text, tables, or figures. | In QOUROM and MOOSE
Graphical presentation of the results | Graphics summarizing individual study estimates and overall estimates were presented. | In MOOSE
Strength (e.g. effect size) of nutrient-outcome associations/effects | The principle measures of effect (e.g., relative risk, odds ratio, risk difference, or absolute difference) were reported. | In QUOROM and MOOSE
Uncertainty of nutrient-outcome associations/effects | Indication of statistical uncertainty of findings (e.g., confidence interval), and/or description on the ranges of estimates (e.g., SD) was reported. | In QOUROM and MOOSE
Analysis (qualitatively or quantitatively) for potential confounding or interactions of the nutrient-outcome association | Assessment of confounding and/or interactions (e.g., comparability of study groups) was reported, or analyzing crude and adjusted effect sizes separately. | In MOOSE
Specific future research recommendations | Specific suggestions for future research agenda (i.e., other than “"more future research is needed") | In QUOROM and MOOSE
Reporting Items for nutrition-related systematic reviews that included intervention studies
Sources of the nutrient interventions | Brand names or components (or formulation) of the nutrient supplements, or foods (or recipes) in the nutrition interventions were reported. | Different forms of nutrients (e.g., all-race-α-tocopherol (chemically synthesized form), RRR-α-tocopherol (naturally occurring form), or γ-tocopherol) may have different health benefits and/or bioavailability in the body.
Doses of the nutrient interventions | The amount of nutrients (or the doses) in the interventions and intervention regimens (e.g., the number of times per day) were reported. | High dose of nutrient supplementations may have harmful health effect (15). Also, the dose is necessary to understand what the intervention was.
Baseline nutrient exposures in the study population | Baseline nutrient exposures or the background diet (i.e., baseline dietary intake levels or the levels of the biomarker of intakes) in the study population were reported. | Data suggest differential effects of nutrient supplementations on the prevention of chronic diseases depending on the background nutrient exposures (16–19).
Reporting Items for nutrition-related systematic reviews included observational studies
Methods/instruments for assessing intakes of nutrient exposures | Methods or instruments for assessing intakes of nutrient exposures (i.e., dietary assessments (FFQ, 24-hour recall, diet record, or diet recall) and/or biomarkers of intakes) were reported. | There are known errors associated with different methods or instruments for assessing dietary intakes. The ideal method or instrument for assessing intakes of nutrient exposures depends on the research question being asked.
Ranges or distributions of the nutrient exposures | Ranges or distributions of the nutrient exposures (i.e., quartiles, mean and SD, or ranges) in the study population were reported. | Ranges or distributions of the nutrient exposures represent the ranges of “doses” of the nutrients in relation to the health outcomes.
Errors in assessing nutrient exposures | Measurement errors of the dietary assessments or biomarkers of intakes were reported or discussed. | Dietary intake cannot be estimated without errors. Some of these errors can be dealt with by analytical techniques (20). Some of these errors can introduce biases.
Potential impacts of the errors from assessing the nutrient exposures on the nutrient-outcome association | Potential impacts of the errors from assessing the nutrient exposures on the nutrient-outcome association were reported or discussed. | The impact of particular type of errors in measuring the nutrient exposures depends on the research question being asked and the analytical methodology used to address it (21).

PI(E)COS, [underlined: P]opulation, [underlined: I]ntervention, [underlined: E]xposure, [underlined: C]omparator, [underlined: O]utcome, and [underlined: S]tudy design; QUOROM, Quality Of Reporting Of Meta-analyses; MOOSE, Meta-analysis of Observational Studies in Epidemiology; FFQ, food frequency questionnaire; SD, standard deviation

* Data were collected for systematic reviews with meta-analyses only

Additional data elements collected included the number of primary studies, instruments or methods used to assess the quality of the primary studies, and the types of primary studies (interventional or observational studies). An interventional study was defined as a study with an active intervention, such as randomized or non-randomized controlled trials, crossover trials, quasi-interventional studies (or community trials), and before-and-after studies. Observational studies included cohort, case-control, cross-sectional and ecological studies, case series and case reports, where the intervention was not dictated by the investigator.

For each SR, we also collected citation counts of the SRs and impact factors of the journals that published these reviews from the Science Citation Index and the Institute for Scientific Information Journal Citation Reports® edition 2006. The impact factor of a journal is calculated based on a three-year period, and can be considered to be the average number of times articles published in the journal are cited up to two years after publication. The citation count is the number of times an article was cited by other articles published in journals indexed in Journal Citation Reports®. Citation counts were collected in February 2008. The mean yearly citation number for each SR was calculated [citation count of SR / (2008-publication year of SR)].

## Statistical Analyses

Descriptive analyses and summary statistics were performed on the reporting characteristics of SRs, including whether the reporting followed published standards such as MOOSE (9) and QUOROM (10), reporting of nutrition variables, number and types of primary studies analyzed, whether quality assessment of primary studies were performed, and what instruments were used to assess quality or susceptibility to biases. Fishers’ exact test was used to examine differences in the proportion of SRs reporting each item, and comparing the SRs that included observational studies to those that included interventional studies.

We used the Mann-Whitney test to examine the differences in the proportion of reporting criteria met by SRs of different study types (interventional studies, observational studies, or both designs), before versus 3 years after publication of QUOROM and MOOSE (in 1999), and SRs with versus without meta-analyses. Correlation analysis was conducted to examine the association between journal impact factors and citation numbers and the proportion of reporting criteria met among SRs. The maximal number of reporting criteria is 29 (26 SR-reporting factors and 3 nutrition variables) for SRs of interventional studies alone, 30 (26+4) for SRs of observational studies alone, and 33 (26+7) for SRs of both designs. Two reporting items for SRs containing meta-analyses (reporting of models for meta-analyses and data needed to calculate the effect size) were excluded from these calculations.

Median and interquartile range (IQR) are reported when the distributions were skewed. All P-values are two-tailed and considered significant when P<0.05.