# Workshop Participants

## Academic Institutions

Stephanie Atkinson, Ph.D; McMaster University

Edward L. Giovannucci, M.D., Sc.D.; Brigham and Women's Hospital

Susan Taylor Mayne, Ph.D.; Yale University School of Medicine

A. Catharine Ross, Ph.D.; Penn State University

Robert Russell, M.D.; Jean Mayer USDA HNRCA

Keith West, Ph.D.; Johns Hopkins University School of Public Health

## Federal Government Agencies/IOM^*^ * Members in this category are participants of the workshop but not authors of this report.

Stephanie Chang, M.D., M.P.H.; AHRQ

Joan M.G. Lyon, M.S., R.D., L.D.; USDA/CNPP

Kathryn Y. McMurry, M.S.; DHHS

Mary Frances Picciano, Ph.D.; ODS, NIH

Christine Taylor, Ph.D.; IOM

Ann Thurn, Ph.D.; ODS, NIH

Paula R. Trumbo, Ph.D.; FDA

Dorothea K. Vafiadis, M.S.; USDA/CNPP

Elizabeth A. Yetley, Ph.D.; ODS, NIH

## Tufts EPC

Joseph Lau, M.D.

Ethan M. Balk, M.D., M.P.H.

Mei Chung, M.P.H.

Deirdre Devine, M.Litt.

Stanley Ip, M.D.

Gowri Raman, M.D.

Thomas Trikalinos, M.D., Ph.D.

Alice H. Lichtenstein, Sc.D.