# Glossary

[underlined: Biomarkers of intake] are measurements of the nutrient itself or a metabolite of the substance in biological samples (e.g., serum selenium) that have been validated to confirm that they reflect the level of intake of that nutrient.

[underlined: Clinical outcome] is a measure of how a patient (or study subject) feels, functions, or survives; or a clinical measurement of the incidence or severity of a disease (e.g., diagnosis of disease).

[underlined: Essential nutrient] is a nutrient required for normal body functioning that cannot be synthesized by the body and must be obtained from a dietary source.

[underlined: Indicator markers (of nutrient intakes)] are measures correlated with dietary intake levels of a nutrient, such as [underlined: biomarkers of intake], [underlined: nutritional status], or [underlined: markers of nutritional status].

[underlined: Marker of nutritional status] is a laboratory measurement or a physical sign that is thought to reflect the early stage of an abnormality (either deficiency or toxicity) of a nutrient intake. Changes induced by a nutritional intervention on the marker of nutritional status are expected to reflect the correction of the abnormality.

[underlined: Nutritional status] is the state of a person's health in terms of the nutrients in his or her diet. Nutritional status is a global term that encompasses a number of specific components from [underlined: nutritional assessments].

[underlined: Nutritional assessment] is a comprehensive approach to define [underlined: nutritional status] using medical, nutrition, and medication histories, physical examination, anthropometric measurement, and laboratory data.

[underlined: Surrogate outcome marker] is a laboratory measurement or a physical sign used as a substitute for a clinical outcome. Changes induced by a therapy on a surrogate outcome marker are expected to reflect changes in a clinical outcome.

Vitamin A Examples:

- Plasma retinol is a [underlined: biomarker of inadequate intake]
- Bone mineral density is [underlined: a surrogate outcome marker] of osteoporosis
- Mortality, xerophthalmia and poor growth status in children are [underlined: clinical outcomes]
- Dark adaptation test is a [underlined: marker of nutritional status]
- Vitamin A deficiency is a [underlined: nutritional status], which is a global term. There are various [underlined: markers of vitamin A deficiency] including an abnormal dark adaptation test (a marker of nutritional status), low plasma retinol (a biomarker of intake), and xerophthalmia (a clinical outcome).