# Acronyms

ADA: | American Dietetic Association
AHRQ: | Agency for Healthcare Research and Quality
AI: | Adequate Intake
CDC: | Centers for Disease Control
DHHS: | Department of Health and Human Services (US)
DRI: | Dietary Reference Intakes
EAR: | Estimated Average Requirement
EBM: | Evidence-based Medicine
EPC: | Evidence-based Practice Center
EU-SCF: | European Union - Scientific Committee on Food
EVM: | Expert Group on Vitamins and Minerals (UK)
FDA: | Food and Drug Administration
FNB [IOM]: | Food and Nutrition Board
IOM: | Institutes of Medicine (US)
NIH: | National Institutes of Health
ODS: | Office for Dietary Supplements
PICO: | Population, Intervention (or exposure), Comparator, Outcome
UL: | Tolerable Upper Intake Level.
USDA/CNPP: | United States Department of Agriculture, Center for Nutrition Policy and Promotion
USPSTF: | United States Preventive Services Task Force