# References

(1) Institute of Medicine. Dietary Reference Intakes. The Essential Guide to Nutrient Requirements. National Academy of Sciences; 2006.
(2) Institute of Medicine. Dietary Reference Intakes. Calcium, phosphorus, magnesium, vitamin D, and fluoride. National Academy of Sciences; 1997.
(3) Institute of Medicine. Dietary Reference Intakes. Thiamin, riboflavin, niacin, vitamin B6, folate, vitamin B12, pantothenic acid, biotin, and choline. National Academy of Science; 1998.
(4) Institute of Medicine. Dietary Reference Intakes. Vitamin C, vitamin E, selenium, and carotenoids. National Academy of Science; 2000.
(5) Institute of Medicine. Dietary Reference Intakes. Vitamin A, vitamin K, arsenic, boron, chromium, copper, iodine, iron, manganese, molybdenum, nickel, silicon, vanadium, and zinc. National Academy of Sciences; 2001.
(6) Institute of Medicine. Dietary Reference Intakes. Energy, carbohydrate, fiber, fat, fatty acids, cholesterol, protein, and amino acids. National Academy of Sciences; 2005.
(7) Institute of Medicine. Dietary Reference Intakes. Water, potassium, sodium, chloride, and sulfate. National Academy of Sciences; 2005.
(8) Institute of Medicine. The development of DRIs 1994-2004: Lessons learned and new challenges—workshop summary. National Academy of Sciences; 2008.
(9) A model for establishing upper levels of intake for nutrients and related substances: report of a Joint FAO/WHO technical Workshop on Food Nutrient Risk Assessment. WHO Headquarters; May 2005.
(10) Users' guides to the medical literature. A manual for evidence-based clinical practice. AMA Press; 2002.
(11) Morris CD, Carson S. Routine vitamin supplementation to prevent cardiovascular disease: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2003;139:56-70. [pmid: 12834320].
(12) National Institutes of Health State-of-the-science conference statement: multivitamin/mineral supplements and chronic disease prevention. Ann Intern Med. 2006;145:364-71. [pmid: 16880454].
(13) Blumberg-Kason S, Lipscomb R. Evidence-based nutrition practice guidelines: A valuable resource in the evidence analysis library. J Am Diet Assoc. 2006;106:1935-6. [pmid: 17126620].
(14) Becker LA, van Binsbergen JJ. How can a proposed Cochrane diet and nutrition field work effectively?. Eur J Clin Nutr. 2005;59(Suppl 1):S167-S171. [pmid: 16052186].
(15) De LM, Salen P. Fish and N-3 fatty acids for the prevention and treatment of coronary heart disease: nutrition is not pharmacology. Am J Med. 2002;112:316-9. [pmid: 11893373].
(16) Counsell C. Formulating questions and locating primary studies for inclusion in systematic reviews. Ann Intern Med. 1997;127:380-7. [pmid: 9273830].
(17) Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20:21-35. [pmid: 11306229].
(18) Moher D, Jadad AR, Nichol G, Penman M, Tugwell P, Walsh S. Assessing the quality of randomized controlled trials: an annotated bibliography of scales and checklists. Control Clin Trials. 1995;16:62-73. [pmid: 7743790].
(19) Schulz KF, Chalmers I, Hayes RJ, Altman DG. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273:408-12. [pmid: 7823387].
(20) Kjaergard LL, Villumsen J, Gluud C. Reported methodologic quality and discrepancies between large and small randomized trials in meta-analyses. Ann Intern Med. 2001;135:982-9. [pmid: 11730399].
(21) Linde K, Scholz M, Ramirez G, Clausius N, Melchart D, Jonas WB. Impact of study quality on outcome in placebo-controlled trials of homeopathy. J Clin Epidemiol. 1999;52:631-6. [pmid: 10391656].
(22) Moher D, Pham B, Jones A, Cook DJ, Jadad AR, Moher M, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352:609-13. [pmid: 9746022].
(23) Balk EM, Bonis PA, Moskowitz H, Schmid CH, Ioannidis JP, Wang C, et al. Correlation of quality measures with estimates of treatment effect in meta-analyses of randomized controlled trials. JAMA. 2002;287:2973-82. [pmid: 12052127].
(24) Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52:377-84. [pmid: 9764259]. [pmcid: 1756728].
(25) Sanderson S, Tatt ID, Higgins JP. Tools for assessing quality and susceptibility to bias in observational studies in epidemiology: a systematic review and annotated bibliography. Int J Epidemiol. 2007;36:666-76. [pmid: 17470488].
(26) Verhagen AP, de Vet HC, de Bie RA, Boers M, van den Brandt PA. The art of quality assessment of RCTs included in systematic reviews. J Clin Epidemiol. 2001;54:651-4. [pmid: 11438404].
(27) The Cochrane Collaboration. The Cochrane Handbook. http://www cochrane.org/resources/handbook/index.htm (http://www.cochrane.org/resources/handbook/index.htm).
(28) Lau J, Ioannidis JP, Schmid CH. Quantitative synthesis in systematic reviews. Ann Intern Med. 1997;127:820-6. [pmid: 9382404].
(29) Miller ER III, Pastor-Barriuso R, Dalal D, Riemersma RA, Appel LJ, Guallar E. Meta-analysis: high-dosage vitamin E supplementation may increase all-cause mortality. Ann Intern Med. 2005;142:37-46. [pmid: 15537682].
(30) Lau J, Ioannidis JP, Schmid CH. Summing up evidence: one answer is not always enough. Lancet. 1998;351:123-7. [pmid: 9439507].
(31) Beard J, Borel M, Peterson FJ. Changes in iron status during weight loss with very-low-energy diets. Am J Clin Nutr. 1997;66:104-10. [pmid: 9209176].
(32) Rock CL, Vasantharajan S. Vitamin status of eating disorder patients: relationship to clinical indices and effect of treatment. Int J Eat Disord. 1995;18:257-62. [pmid: 8556021].
(33) Wortsman J, Matsuoka LY, Chen TC, Lu Z, Holick MF. Decreased bioavailability of vitamin D in obesity. Am J Clin Nutr. 2000;72:690-3. [pmid: 10966885].
(34) Blanck HM, Bowman BA, Cooper GR, Myers GL, Miller DT. Laboratory issues: use of nutritional biomarkers. J Nutr. 2003;133(Suppl 3):888S-94S. [pmid: 12612175].