# Integrating Systematic Review Into a Process to Establish Nutrient Reference Values

As mentioned above, an analytic framework is a useful graphical representation of the perceived relationships between the nutrient of interest and the associated health outcome. It provides several advantages to both reviewers and readers of systematic reviews by illustrating linkages among nutrients, other substances of interest, co-morbid conditions, and intermediate endpoints, and their interactions and sequential effects on clinical outcomes. It is a conceptual representation of the plausible underlying biology, simple enough to study and complex enough to capture the most relevant relationships. By depicting the chain of logic that evidence must support to link the nutrient exposures to clinical outcomes, this process helps guide the development of answerable key questions, define study eligibility criteria, and interpret and contextualize relevant studies.

## Generic Analytic Framework for Nutrient Reference Values

Figure 2 shows an example of a generic analytic framework. The framework describes the relationships between “exposure” (nutrient intake) and clinical outcome(s) of interest. The components of the generic framework are described below in more detail. Not all components would be considered for all nutrients or all questions for a specific nutrient; therefore, actual analytic framework needs to be developed for each nutrient of interest.

Figure 2. Generic Analytic Framework applicable to assessment of nutrients. A representation of the putative associations between an exposure (e.g., a nutrient) and indicator markers of intake (e.g., serum or tissue nutrient levels), (non-validated) intermediate outcomes, (valid) surrogate markers, and clinical outcomes. The arrows represent associations among factors. Line thickness represents the relative “directness” of an association, and the strength of the relationship with clinical outcomes. Dotted lines represent associations to surrogate markers for which there is no good evidence of an association with clinical outcomes

The generic analytic framework can be thought of as a template to be modified to reflect the underlying biological factors associated with a specific nutrient. Furthermore, different generic analytic frameworks will be needed to describe the exposure and clinical outcome, including the intermediate factors, for the different types of nutrient reference values because the criteria for exposure and clinical outcomes will be different. For example, developing reference values for a reference value for a nutrient level that meets the needs of ~50 percent of the population, versus a reference value for an excessive intake level.

### Clinical Outcomes

Clinical outcomes can be perceived by a study subject, and their improvement (or not worsening) is preferable to outcomes that cannot be perceived by a study subject, for examples bone fractures, depression, chronic fatigue, quality of life, or angina pectoris due to atherosclerotic coronary disease. For the purposes of this discussion “anemia” is not considered a clinical outcome. “Fatigue” would be the corresponding clinical outcome. Adverse events would also be considered as clinical outcomes.

An additional caveat pertains to the distinction between “hard” and “soft” clinical outcomes. Hard outcomes, such as mortality, stroke, myocardial infarction, or fractures can be objectively assessed. Soft outcomes, such as feeling depressed, chronic fatigue, or quality of life are subjective and their evaluation or measurement may be more susceptible to the interplay of systematic errors and biases compared to hard outcomes.

### Valid Surrogate Outcome Markers

Because most often there are few or no studies that directly link specific nutrient intakes with clinical outcomes, intermediate (surrogate) outcomes need be considered. Typically, we would consider only validated surrogates of the clinical outcome. These are outcomes that are strongly correlated with the clinical outcome (e.g., bone mineral density is a valid surrogate for fractures), and changes in their status reflect corresponding changes in the risk for the clinical outcome (e.g., changes in bone mineral density generally reflect changes in fracture risk). In contrast, homocysteine levels are not a valid surrogate endpoint for cardiovascular disease risk: intervention-induced changes in homocysteine levels (e.g., by increasing folate consumption) do not correspond to changes in the risk for cardiovascular disease.

### Non-validated Intermediate Outcome Markers

Non-validated intermediate markers are possible predictors of clinical outcomes that have not been proven to fulfill the criteria for a validated surrogate outcome. However, in the absence of validated surrogate outcomes, one might consider such intermediates as the next best available evidence. An example would be absence of anemia as an intermediate marker for the absence of disease (well-being), or serum osteocalcin (a bone turnover index) as an intermediate marker for fractures. When considering non-validated intermediate markers the implicit assumption is that they would have the properties of a validated surrogate outcome. Not only should this assumption be made explicit, but the uncertainties involved in applying this assumption should also be identified and discussed. To emphasize this, the corresponding links in the generic framework in Figure 2 are indicated with dashed lines.

### Indicator Markers (of Nutrient Intake)

Although the ultimate goal is to provide nutrient reference values for all essential nutrients, it may be preferable to associate clinical outcomes with an indicator (or biomarker) for the corresponding nutrient when reliable indicator (or biomarker) are available. A reliable indicator (or biomarker) fulfills the classical assessment model (i.e. linear, dose-response model) with an error that is independent of that for (self-reported) nutrient consumption estimates. Using a reliable indicator of dietary intake (e.g., serum levels for vitamin C) can enhance objectivity because estimates of intake are not affected by subjects' memory or ability to accurately report food intake, or the accuracy of the database used to estimate nutrient intake from food intake data. However, readily available indicators of nutrient exposure, more frequently blood and urine, are often under homeostatic control and do not represent good markers of nutrient status. Moreover, like the error and variation associated with dietary intake measures, the magnitude and impact of both biological (preanalytical) and laboratory (analytical) variability need to be considered when using biomarkers. ^34^

Using a biomarker to evaluate the strength of downstream associations requires that the biomarker levels be back-translated into levels of nutrient intake. Thus, if an association is found between a given biomarker level and risk of a clinical outcome, an estimate of the nutrient intake level that corresponded with the clinical outcome would likewise be necessary. This step has proven to be challenging.

## Decision-making for Questions and Outcomes of Interest

An important aspect of the decision-making is which questions should be addressed by systematic reviews and which questions will either not be addressed or will be addressed by other methods. For systematic reviews, answerable research questions need to be formulated. After organization of general topics and questions based on the linkages in the analytic framework, detailed determinations are needed to define the parameters of the systematic review(s).

Following the PICO format, first the population of interest is defined. Nutrient reference values are needed for specific categories (based on age, gender and pregnancy status) of generally healthy Americans. However, to operationalize this in reviewing studies, it is necessary to make judgments about what health conditions and nutritional status are of interest, are allowable, and should be excluded. These decisions can be quite complex and need to be made in light of what is known about how the nutrient affects or is affected by conditions such as cancer, infections and malnutrition. Other considerations that contribute to heterogeneity of populations across studies include varied study designs (differences in patient or participant sampling), background diets, and studies conducted in different environments.

The interventions or exposures of interest need to be defined. In contrast with pharmaceuticals, for nutrients it is common that there is a range of substances (that may not yet be fully elucidated) that are active and interact with each other, such as the different forms of vitamins A and D, or multiple minerals altering gut bioavailability. Furthermore, the principal source of nutrients is food or dietary supplements, which are consumed against background levels of exposure, in contrast to precisely dosed pharmaceuticals that generally are the only exposure source. Thus, decisions are needed regarding which forms of the nutrient are of interest and what methods for measuring their intake are appropriate, taking into account the strengths and limitations of the dietary assessment methods and of the quality of the food composition database. For many nutrients acceptable measurements of intake are not readily available. In this case, alternative to a “subjective” decision-making process to choose which measurements of intake to be evaluated would be desirable. An “objective” evidence map to capture and present the information on what dietary assessment method and which food composition database was used, and how well the statistical model dealt with the measurement error inherent in the dietary intake assessment (and in any biomarkers) in all studies will help a transparent decision-making process.

The possible comparators of interest are generally related to the study designs that will be included. Many nutrition studies are observational studies (whether cross-sectional or longitudinal) that estimate and analyze nutrient intake as a continuous variable across a range of intakes or create quantiles or other categories to describe intake. The appropriateness of these approaches and of the threshold used to categorize the intake need to be defined. In nutrition studies it may also be necessary to account for the co-varying of multiple nutrients in the diet. For example, any reduction of one macronutrient (e.g., saturated fat or animal protein) must be accompanied by an increase in other macronutrients (e.g. carbohydrate) to maintain weight. It may thus be difficult to ascertain whether potential outcomes are related to changing the macronutrient of interest (e.g., soy protein) or to what replaced that macronutrient (e.g., milk protein). Similarly, the possibility that differences in intake of the micronutrient of interest may be correlated with other dietary differences (e.g. changes in vitamin E intake with changes in the fatty acid profile of the diet).

Clearly defining the outcomes of interest is critical to focusing the systematic review questions to those topics that are relevant to determining nutrient reference values. The types of outcomes are different depending on the analytic framework linkage being addressed. These may include human tissue (e.g., serum, liver, erythrocyte) levels, surrogate or intermediate markers of disease (e.g., lipoproteins, blood pressure, inflammatory markers), or clinical outcomes (e.g., cancer, cardiovascular disease, death). In general, the ultimate question of interest is what levels of intake (whether too little or too much) are associated with poor clinical outcomes. However, studies that directly address this question are relatively rare. Judgments need to be made about how reliably surrogate outcomes or disease markers predict clinical outcomes.

Prior to conducting literature searches and analyzing the data the study designs of interest (e.g., randomized controlled trials, other comparative trials, prospective or retrospective analyses, cross-sectional or longitudinal studies, adjusted or unadjusted analyses) need to be established. In addition, the year that studies were conducted should be part of the inclusion criteria because for many topics the earliest studies may no longer be relevant. One needs to take into consideration how the science (e.g., measurement tools for exposures and outcomes) may have changed or possibly how dietary, exercise, or other health-related factors have changed. It is also necessary to determine the minimum number of subjects that should be included and, depending on the study design, the minimum duration of follow-up. These decisions may be somewhat arbitrary but they balance the need to focus the review on the studies most likely to provide useful results with the need to often incorporate sparse data. Very small studies (e.g., case series) may provide useful lists of potential adverse events but are unlikely to provide precise estimates of effect sizes. Studies of “too” short a duration may be inadequate to estimate outcomes of interest (e.g., change in lipoprotein level or cancer incidence).