# Systematic Review Methods

## Overview

A systematic review is a protocol driven comprehensive review and synthesis of data focusing on a topic or on related key questions. It is typically performed by experienced methodologists with the input of domain experts.

The first step to conduct a systematic review is to formulate specific key questions. For situations that involve addressing more than a single, simple question, it is often useful to construct an analytic framework (evidence model) depicting the key questions being addressed to help appreciate their relationships. Furthermore, when many questions are being addressed, it may be beneficial to construct an “evidence map”, an exploratory exercise that informs on the amount of evidence potentially relevant to different questions. This information can aid in more detailed planning to allocate resources and ensure a timely completion of the project. Additional essential steps include developing a protocol, refining the questions of interest, conducting a literature search for evidence, selecting studies that meet the inclusion criteria, appraising the studies critically, and synthesizing and interpreting the results.

These steps are briefly described in this section. As mentioned above, systematic reviews should be carried out as a collaborative activity by individuals knowledgeable in the evidence-based methods and those with expertise in the questions of interest. As systematic reviews are increasingly being published on nutrition related topics, the term systematic review has been subjected to various modifications to include evidence-based review, systematic evidence-based review, and evidence-based systematic review. In this report, we use the term systematic review, which is the longstanding common usage in medicine and other disciplines.

### Key Question Formulation

Overarching questions such as “What should be the upper intake level for vitamin A?” cannot be answered directly from primary data in the literature although the answer may be the ultimate goal of the exercise. The question must be dissected into smaller and more specific questions that individual studies can address. Multiple systematic reviews will then address these individual questions and the results will be synthesized according to a predefined framework. Thus, a vital step in performing a systematic review is formulating clearly stated research questions that would be amenable to literature review. “Key questions” are analogous to the hypotheses of primary research studies; they should be focused and explicitly stated because they define the scope of research the systematic review will address. Key questions are commonly formulated according to the “PICO” method, which defines the Population, the Intervention (or exposure in the case of observation studies), the appropriate Control or Comparator, and the Outcomes of interest. ^16^ Describing the inclusion criteria for each of the PICO elements clearly provides the investigators the opportunity to understand the specific questions being asked - and equally important, what questions are not being asked - in the systematic review. This step ensures reproducibility and transparency, and it guides the determination of study eligibility, data extraction, analysis, and interpretation of results. The reviewers must also decide which study designs are acceptable to answer specific questions. The choice about the types of evidence to be included is often a balance between what evidence is needed for conclusive answers to the review questions and the limitations of published studies. While randomized controlled trials may be ideal, these studies are often not practical or feasible, and other sources of evidence may need to be evaluated.

### Analytic Framework

To guide assessment of studies that addresses the topic of interest, it is helpful to develop an analytic framework that visually maps the specific linkages associating the populations of interest, exposures, modifying factors, and outcomes of interest (Figure 1). ^17^ The framework graphically presents the key components of the study questions:

- Who are the participants (i.e., what is the population and setting of interest, including the diseases or conditions of interest)?
- What are the interventions or exposures?
- What are the outcomes of interest (intermediate and clinical outcomes)?
- What study designs provide data that can help answer the question?

Figure 1. An example of a generic analytic framework used by the U.S. Preventive Services Task Force (USPSTF). ^17^ Each number represents a specific link or answerable research question. A generic analytic framework for nutrient reference values is shown in Figure 2

Specifically, the analytic framework depicts the chain of logic that evidence must support to link the intervention or exposure to improved health outcomes. This process helps guide the development of key questions. The framework can also provide a basis for interpreting and contextualizing relevant studies, and establishing which links in the chain of logic are answered, inconclusive or not yet addressed.

### Evidence Mapping to Inform the State of Evidence in a Particular Topic

Evidence mapping is a method to facilitate exploring new ideas and hypotheses. It can be used to direct limited resources to potentially more fruitful areas for systematic review as well as to complement comprehensive systematic reviews on specific key questions. It aims to provide investigators with information about the type and amount of research available, the characteristics of that research, and the topics where a sufficient amount of evidence has accumulated for synthesis.

Individual systematic reviews are labor intensive activities and might require the evaluation of hundreds of articles before identifying a handful of studies meeting the predetermined eligibility criteria. An evidence map to provide a “bird's eye” view requires only a fraction of the resources needed to produce a full systematic review, allowing users to appreciate the depth, breadth, and characteristics of research in a particular area before investing valuable resources in a full systematic review. Evidence mapping is a cost-effective method to inform users of the current state of research findings that could be used to generate hypotheses, inform ongoing research, and identify research gaps.

### Critical Appraisal

The quality of an individual study has been defined as the “confidence that the trial (study) design, conduct, and analysis has minimized or avoided biases in its treatment (exposure) comparison.” ^18^ Quality assessment may suggest the extent to which a study's design and methodology prevented systematic error, and may explain differences in the results among systematic reviews. However, implementing and interpreting the results of quality assessment is not straightforward. Numerous approaches have been proposed to assess the quality of studies and apply these assessments to systematic reviews. Until recently, checklists and quality scales, generally comprised of several to several dozen factors believed to be associated with study quality, were commonly used.

Among the more common quality indicators for intervention trials are adequate concealment of random allocation, accurate reporting of withdrawals, degree of reporting accuracy, appropriateness of statistical analysis, and blinding in the assessment of outcomes. In theory, studies in which these measures are poorly achieved are more likely to result in biased outcomes. For example, compared to double-blinded studies, non-blinded studies may exaggerate the benefit of treatment (e.g. a larger odds ratio, or treatment effect). Of those criteria assessed, only lack of concealment of randomization and double blinding, with limited empirical evidence, have been shown to be related to exaggerated estimates of treatment effects. ^19^ However, other studies evaluating the importance of these quality measures have differed regarding the extent to which they were related to effect sizes. ^20^ – ^22^ Furthermore, individual quality measures may not be consistently associated with the magnitude of treatment effect across studies and medical areas. ^23^ As a result, methods that arbitrarily weight these measures to establish quality scores for studies are no longer deemed appropriate.

Approaches to assessing the quality of observational studies have been proposed; ^24,^ ^25^ however, there are no empirical data validating any of these methods. The assessment of study quality is limited by the need to rely on author-supplied information and an understanding that there is no true reference standard for quality. ^26^ Critical appraisal of individual studies should be performed as part of a systematic review, but the results should be interpreted cautiously. The primary value may be to explore possible reasons for differences in results among studies. No specific instrument has been proposed to assess the quality of nutrition studies for the purpose of systematic review, although several factors (e.g., methods to assess dietary intake, quality of the statistical models used, independent replication of results from two or more laboratories) have been identified as important to consider based on the theoretical assumption that failure to adhere to the item proposed could lead to biased results.

### Evidence Synthesis

A systematic review often identifies several studies addressing the same question. The results of these studies need to be synthesized and interpreted. Synthesis of the findings of different studies can be done qualitatively or quantitatively. It is not necessary for a systematic review to include quantitative analyses of individual study findings; however, when possible, quantitative analyses should be preferred over qualitative-only synthesis. Because quantitative synthesis has strengths and limitations, we briefly describe it below. An authoritative discussion on meta-analysis can be found in the Cochrane Handbook. ^27^

The quantitative synthesis of results obtained from different studies is termed meta-analysis. ^28^ By aggregating information from different studies, meta-analysis can increase statistical power and provide answers that no single study can give (i.e., detect modest associations, or conversely, exclude the presence of clinically important effects). For example, a meta-analysis of 19 clinical trials found a statistically significant increased overall mortality in participants who received “high doses” of vitamin E; ^29^ levels that had previously been considered as well below the upper limit, a finding that was not statistically significant in most of the individual studies. Of equal importance, meta-analysis quantifies between-study heterogeneity (between-study dissimilarity), and provides tools (e.g., meta-regression) to explain it. ^30^ Finally, meta-analysis facilitates the evaluation of systematic errors and biases, and their effect on any given topic.

Meta-analysis has sometimes been criticized as an inappropriate exercise of combining apples and oranges. Deciding when a meta-analysis is appropriate can be a challenge as there are numerous sources of heterogeneity that one needs to consider. If the designs, quality, and results of the studies are deemed to be so heterogeneous, then statistically combining them can yield misleading conclusions. In such cases where meta-analyses are deemed inappropriate, the data should be organized and presented in an analytic framework, and in summary evidence tables. This approach will help clarify the similarities and differences among studies that appear to address similar research question (qualitative synthesis).

### Potential Challenges in Applying Evidence-based Methods to Support the Setting of Nutrient Reference Values

While the basic methodologies employed in systematic reviews of medical topics can be adapted to nutrition topics, there are also challenges and unique problems when incorporating the process into approaches to establish nutrient reference values. Many of these potential issues are unique to individual nutrients. Taking these factors into account while formulating the systematic review questions will minimize the risk of generating uninformative or wrong answers. The relative importance of each issue is nutrient specific. This section serves to provide a general discussion of potential issues to consider.

Many nutrients naturally occur in multiple bioactive forms. It is important to determine whether generally accepted nutrient conversion factors are valid in cases of marginal or excess intakes. The background or habitual diet of the study subjects is a critical factor that must be accounted for when extracting data from individual study reports. Response to deletion or supplementation of a nutrient will differ on the basis of this factor. It is important to document the nutrient status of the subjects prior to intervention, the status of body stores, and the potential bioavailability of those stores. It is also important to document body weight changes. Weight loss can result in hormonal changes and subsequent release of certain nutrients (e.g. iron status) not normally available. ^30,^ ^31^ Alternatively, weight gain can create nutrient reservoirs (e.g. fat soluble vitamins) that are unavailable in times of nutrient, but not energy, need. ^30,^ ^32,^ ^33^

Some factors are particularly important and should be taken into account when data from multiple populations are examined. These include differences in nutrient bioequivalency that depend on the type of natural or fortified foods available to the general population (e.g. heme and nonheme iron); differences in food processing techniques (e.g. lye treated corn and niacin); and differences in whether the major source of the nutrient is limited to naturally occurring forms or whether a synthetic form is commonly added to in the food supply (e.g. folate and enriched grains). The increasingly common practice of supplementing foods with nutrients may also need to be accounted for (e.g. nutrient-fortified soft drinks, calcium-fortified orange juice). Additional factors that are important in cross-cultural comparisons include nutrient bioavailability as altered by coingestion of other foods, supplemental nutrients or drugs, and non-food sources of a nutrient (e.g. sun exposure and vitamin D, gut microflora and vitamin K).