# List of Acronyms/Abbreviations

Abbreviations used: AHRQ, Agency for Healthcare Research and Quality; CONSORT, consolidated standards of reporting trials; DHA, docosahexaenoic acid; EPA, eicosapentaenoic acid; GRADE, grading recommendations assessment, development and evaluation; PICO, population, intervention, comparator and outcomes.