# Introduction

Systematic reviews represent a rigorous approach to synthesize and evaluate scientific evidence.^(1)^ This approach to summarize available data minimizes potential reporting bias through comprehensive and reproducible searches using clearly defined and described selections and reporting protocols. The systematic review approach enhances rigor by assessing the methodological quality of the included studies and overall strength of the body of evidence. Transparency of the process is ensured through detailed documentation of the decision making process. An analytic framework helps to clarify key questions and delineate the connecting logic between them. The tables used to summarize study characteristics and findings stand alone as independent scientific publications that can be used to document the state of the scientific evidence, provide input into program and policy decision-making processes, identify knowledge gaps and research needs, and serve as the foundation for later updates as new data emerge. The objectivity of systematic reviews comes from the approach used to review the literature with its requisite documentation and also from the involvement of individuals trained in systematic review methodologies who are unlikely to have a vested interest in the particular nutrient/disease relationship outcome and pre-defined procedures for ensuring independence of the scientific review decisions from persons who may carry preconceived ideas or personal biases into the process. Examples include investigators whose studies may be considered in the systematic review process or persons and groups who may have vested interests in the outcome of the review such as sponsors, users, consumer advocacy, and industry groups.

There is a long history for the use of systematic reviews in the medical community to develop clinical and public health practice guidelines ^(2, 3)^, set research agendas ^(1)^ and formulate scientific consensus statements.^(4, 5)^ The use of systematic reviews to address nutrition related issues is more recent. ^(6–10)^ Nevertheless, there is a wide range of nutrition applications for which a systematic review process has been used or is being considered (Table 1). Although many of these applications are similar to those used in the areas of medicine and public health, characteristics unique to nutrition related topics (e.g., essentiality, habitual exposure) necessitate the development of a more complex set of research questions and approaches to the decision-making process than have traditionally been encountered in other fields.^(11)^ It should be noted that as systematic reviews are increasingly being performed and published for nutrition related topics, the term systematic review has been subjected to various modifications to include evidence-based review, systematic evidence-based review, and evidence-based systematic review. In this article, we use the term systematic review, which is the common usage in medicine and other disciplines.

Table 1 Examples of current and potential uses of systematic reviews in nutrition applications

Nutrition Application | Examples of Applications | Citation
Identify research needs and priorities | • (n-3) Fatty acids and cardiovascular disease | (39)
| • Multivitamin/mineral supplements and chronic disease prevention | (40)
| • Vitamin D and Bone Health | (41)
Formulate dietary guidelines | • 2005 Dietary Guidelines for Americans | (42)
| • 2008 American Diabetes Association Nutrition Recommendations | (43)
Establish nutrient reference intakes | • Derive estimates of average requirements and acceptable upper levels of intake. | (11) (44)
Formulate clinical practice guidelines | • Screening for Iron Deficiency Anemia —Including Iron Prophylaxis | (45)
| • Counseling for a Healthy Diet | (46)
| • Pediatric Weight Management | (47)
Formulate community practice guidelines | • Multi-component school-based nutrition programs | (48)
Evaluate applications for food and supplement label health claims | • Tomatoes, lycopene, and cancer | (49)
| • Lutein and zeaxanthin intakes and risk of age-related macular degeneration and cataracts | (50)

Understanding the basic components of the systematic review approach and how it can be adapted to address a wide range of nutrition related questions is critical to maximizing its utility and gaining wider acceptance. It is important to appreciate that the systematic review approach is flexible and can accommodate unique challenges posed by questions related to food and nutrition. It is equally important to understand that the focus of a systematic review is to provide answers to specific questions. These questions may be just a few among many needed to address an overarching topic. The answers to these questions do not constitute recommendations. Users of systematic reviews (e.g., government agencies, expert panels) must combine the results of a systematic review with other information and expert judgment to formulate clinical or public health policies. The intent of this article is to describe the steps used to perform systematic reviews and measures to ensure the integrity of the reviews to minimize bias, identify areas unique to the discipline of nutrition that should be factored into an evidence review process prior to undertaking the task, and discuss the strengths and limitations of systematic reviews for users of these reviews in setting recommendations and guidelines and other nutrition applications. We also identify areas for future consideration.

## Examples of Recent Systematic Reviews of Nutrition-Related Topics

Three examples of systematic review applications are summarized for nutrition related topics:

1 Effectiveness and Safety of Vitamin D in Relation to Bone Health, ^(10)^
2 Effects of Soy on Health Outcomes, ^(12)^ and
3 Health Effects of (n-3) Fatty Acids on Arrhythmogenic Mechanisms in Animal and Isolated Organ/Cell Culture Studies (Table 2). ^(13)^

Table 2 Systematic review steps and examples from nutrition-related topics^1^

[underlined: Systematic Review Step] | [underlined: Examples]
| Vitamin D and Bone Health (10) | Soy and Health Outcomes (12) | (N-3) Fatty Acids and Arrhythmogenic Mechanisms (13)
Form multidisciplinary research team (in addition to systematic review methodologists and systematic review sponsors) | Domain experts in nutrition, endocrinology, pediatrics, and biochemistry | Domain experts in soy research and relevant health areas | Domain experts in (n-3) fatty acids research and cardiac electrogenesis and arrhythmia outcomes
Develop analytic framework | Related intakes, serum 25(OH)D, active form (1,25(OH)D) and bone health | Not available | Different for whole animal, intact animal isolated organ and cell, and cell culture studies
Develop and refine key questions | Serum 25(OH)D and bone health Intake or sun exposures and serum 25(OH)D Vitamin D intakes and BMD, fractures or falls; variation with age, ethnicity, geography, BMI Sunlight and 25(OH)D without ↑ skin cancer Intakes related to toxicities | Soy formulations, doses, and purposes in trials Whole soy or soy constituents and heath outcomes Dose-response of soy forms or constitutions Frequency and type of adverse effects Dose-response of whole soy and constituents on safety | Evidence from whole animal studies that (n-3) fatty acids affect arrhythmogenic outcomes Evidence from cell culture and tissue studies that (n-3) fatty acids directly affect cell organelles involved in electrogenesis
Define eligibility criteria | Some questions limited to RCTs Some questions included prospective cohorts, case-control and before-after studies. One question restricted to existing systematic reviews Included studies that assessed vitamin D2 or D3 with or without calcium supplementation Excluded studies that used calcium with vitamin D as a control arm unless a placebo was available as a comparator; vitamin D preparations calcitriol or alphacalcidol; studies on the efficacy of vitamin D for the treatment of secondary causes of osteoporosis or for treatment of vitamin D-dependent rickets | Inclusions: subjects ≥ 13 y; RCTs, cohorts, cross-over and non-randomized comparison studies; ≥5 subjects in soy arm; any health condition; quantification of soy intake; outcomes of interest;. ≥ 4 wk duration Exclusions: soy mixed with other ingredients; soy enteral feedings; reviews; non-trial observational studies; animal or in vitro studies; ingested soy not quantified; insignificant amounts of soy; no intake data | Inclusions: experiments of (n-3) fatty acids and arrhythmia, intermediate mechanisms of arrhythmia, and electrogenesis Exclusions: letters or abstracts; mechanisms related to eicosanoids, enzymes, receptors, membrane composition, fluidity, or phospholipids; non-mammalian animals or cell lines; no relevant outcomes; no (n-3) fatty acids intervention; reviews; safety assessments
Identify search terms and strategy | 130 key terms | 33–63 key terms per search | 64 search terms
Screen abstracts according to eligibility criteria | 6566 unique records | ~ 4800 abstracts | 1807 abstracts
Articles retrieved for evaluation | 1447 reports | 599 full text articles | 274 articles
Extract data from articles which met inclusion criteria | 167 articles | 178 articles | 89 articles
Construct evidence and summary tables | 18 summary tables | 86 summary tables | 31 summary tables
Assess methodological quality, applicability | Jadad scale for RCT Good, fair, or consistent rating for observational studies | 3-categories (A,B,C) of methodological quality 3-category applicability grade | 4-categories for fatty acid and/or level of fat in the comparison diet
Perform meta-analyses, as appropriate | Meta-analysis of RCTs that assessed interventions, populations and outcomes | Meta analysis for several cardiovascular outcomes Meta-regression of differences across studies and dose-responses | Meta analyses for whole animal studies For isolated organ and cell studies, qualitative data summary
Synthesize results, write report, have report reviewed | Report written by EPC; peer review by TEP members and external reviewers | Report written by EPC; peer review by TEP members and external reviewers | Report written by EPC; peer review by TEP members and external reviewers

1 EPC, Evidence-based Practice Center; FA, fatty acid; RCT, randomized controlled trial; TEP, technical expert panel

These examples were selected because they serve to illustrate the comprehensive and flexible nature of the systematic review process. Although similar steps were followed, they were conducted by two EPCs (Tufts Medical Center Evidence-based Practice Center and University of Ottawa Evidence-based Practice Center). The inherent flexibility of the systematic review methodology is illustrated by the topics that address issues related to a single nutrient, vitamin D and bone health, complex nutritional interventions, soy protein/isoflavones and health outcomes, and multiple experimental models and outcomes, n-3 fatty acids and animal/isolated organ/cell culture. They also include study design foci that address issues related to animal/in vitro, n-3 fatty acids, combination of observational and intervention human studies, soy and health outcomes, exclusive reliance on randomized clinical trials, and several questions for vitamin D and bone health.