# Abbreviations

AHRQ | Agency for Healthcare Research and Quality
CCJ RCT | Abbreviation use for one of the search strategies tested. CCJ is the Core Clinical Journals, a MEDLINE journal subset previously known Abridged Index Medicus.
CCT | Controlled clinical trial
CQ | Abbreviation use for one of the search strategies tested - Clinical Queries
CR | Abbreviation use for one of the search strategies tested - Citing References
EPC | Evidence-Based Practice Center
HR | Hazard ratio
HTA | Health Technology Assessment
ISI Science Citation | ISI is Institute for Scientific Information
IRQ | Inter-quartile range
MeSH | Medical Subject Headings - the term describes the MEDLINE thesaurus
PMID | PubMed unique identifier
RCT | Randomized controlled trial
RA RCT | Abbreviation use for one of the search strategies tested - Related Article RCT