# Listing of Excluded Studies

1 ___. Anonymous. ISIS-4: a randomised factorial trial assessing early oral captopril, oral mononitrate, and intravenous magnesium sulphate in 58 050 patients with suspected myocardial infarction. Lancet 1995;345(8951):669–82. Not an SR.
2 Abramson M J, Puy R M, Weiner J M. Allergen immunotherapy for asthma. Cochrane Database of Systematic Reviews 2003;(4). Overlap with earlier SR on same topic.
3 Alberts MJ, Hademenos G, Latchaw RE, et al. Recommendations for the establishment of primary stroke centers. JAMA. 2000;283:3102-9. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 10865305].
4 Alderson P, Bunn F, Lefebvre C. Human albumin solution for resuscitation and volume expansion in critically ill patients. Cochrane Database of Systematic Reviews 2002;(1). Overlap with earlier SR on same topic.
5 Alejandria M M, Lansang M A, Dans L F et al. Intravenous immunoglobulin for treating sepsis and septic shock. Cochrane Database of Systematic Reviews 2001;(2). Overlap with earlier SR on same topic.
6 Aligne CA, Stoddard JJ. Tobacco and children : an economic evaluation of the medical effects of parental smoking. Arch Pediatr Adolesc Med. 1998;151:648-53. Review of a non-therapeutic topic. [pmid: 9232036].
7 Allen C, Glasziou P, Del Mar C. Bed rest: a potentially harmful treatment needing more careful evaluation. Lancet. 1999;354:1229-33. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 10520630].
8 Alper BS, Lewis PR. Does treatment of acute herpes zoster prevent or shorten postherpetic neuralgia? A systematic review of the literature. J Fam Pract. 2000;49:255-64. Focused on ineligible therapy. [pmid: 10735485].
9 Alper BS, Lewis PR. Treatment of postherpetic neuralgia: A systematic review of the literature. J Fam Pract. 2002;51:121-8. Focused on ineligible therapy. [pmid: 11978209].
10 American College, of Physicians. Guidelines for using serum cholesterol, high-density lipoprotein cholesterol, and triglyceride levels as screening tests for preventing coronary heart disease in adults. Ann Intern Med. 1996;124(5):515-7. Review of a non-therapeutic topic. [pmid: 8602714].
11 Amiodarone Trials, Meta-Analysis Investigators. Effect of prophylactic amiodarone on mortality after acute myocardial infarction and in congestive heart failure: meta-analysis of individual data from 6500 patients in randomised trials. Lancet. 1997;350(9089):1417-24. Ineligible MA type. [pmid: 9371164].
12 Anderson JW, Johnstone BM, Cook-Newell ME. Meta-analysis of the effects of soy protein intake on serum lipids. N Engl J Med. 1995;333(5):276-82. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 7596371].
13 Annane D, Bellissant E, Bollaert PE. Corticosteroids for severe sepsis and septic shock: a systematic review and meta-analysis. BMJ. 2004;329(7464):480-8. Overlap with earlier SR on same topic. [pmid: 15289273]. [pmcid: 515196].
14 Anthonisen NR, Skeans MA, Wise RA. The effects of a smoking cessation intervention on 14.5-year mortality: a randomized clinical trial. Ann Intern Med. 2005;142:233-9. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 15710956].
15 Antonelli M, Conti G, Rocco M. A comparison of noninvasive positive-pressure ventilation and conventional mechanical ventilation in patients with acute respiratory failure. N Engl J Med. 1998;339:429-35. Not an SR. [pmid: 9700176].
16 Astin JA, Harkness E, Ernst E. The efficacy of “distant healing”: a systematic review of randomized trials. Ann Intern Med. 2000;132:903-10. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 10836918].
17 Ausejo M, Saenz A, Pham B. The effectiveness of glucocorticoids in treating croup: meta-analysis. BMJ. 1999;319:595-600. Ineligible outcome format. [pmid: 10473471]. [pmcid: 28209].
18 Balas EA, Jaffrey F, Kuperman GJ. Electronic communication with patients : evaluation of distance medicine technology. JAMA. 1997;278(2):152-9. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 9214532].
19 Barbui C, Hotopf M, Freemantle N. Selective serotonin reuptake inhibitors versus tricyclic and heterocyclic antidepressants: comparison of drug adherence. Cochrane Database of Systematic Reviews 2000;(4):MA only of non-clinical measures.
20 Barr RG, Rowe BH, Camargo CA. Methylxanthines for exacerbations of chronic obstructive pulmonary disease: meta-analysis of randomised trials. BMJ. 2003;327:643-8. Summary statistic was continuous, not WMD. [pmid: 14500434]. [pmcid: 196388].
21 Beilby JJ, Silagy CA. Trials of providing costing information to general practitioners: a systematic review. Med J Aust. 1997;167(2):89-92. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 9251695].
22 Bent S, Saint S, Vittinghoff E, et al. Antibiotics in acute bronchitis: a meta-analysis. Am J Med. 1999;107:62-7. Summary statistic was continuous, not WMD. [pmid: 10403354].
23 Croft A M, Garner P. Mefloquine for preventing malaria in non-immune adult travellers.. Cochrane Database of Systematic Reviews 2000;(2):Focused on ineligible therapy.
24 Crowley P. Interventions to prevent, or improve outcome from, labour at or beyond term. Cochrane Database of Systematic Reviews 1997;(2):Focused on ineligible therapy.
25 Crystal E, Connolly SJ, Sleik K, et al. Interventions on prevention of postoperative atrial fibrillation in patients undergoing heart surgery: A meta-analysis. Circulation. 2002;106:75-80. Focused on ineligible therapy. [pmid: 12093773].
26 Cullum N, Deeks J, Sheldon T A et al. Beds, mattresses and cushions for pressure sore prevention and treatment. Cochrane Database of Systematic Reviews 1999;Not clinical benefit or harm of a specific (class of) drug, device or procedure.
27 Damoiseaux RA, van Balen FA, Hoes AW, et al. Primary care based randomised, double blind trial of amoxicillin versus placebo for acute otitis media in children aged under 2 years. BMJ. 2000;320:350-4. Not an SR. [pmid: 10657332]. [pmcid: 27282].
28 Davis D, Thomson O'Brien MA, Freemantle N. Impact of formal continuing medical education : do conferences, workshops, rounds, and other traditional continuing education activities change physician behavior or health care outcomes?. JAMA. 1999;282:867-74. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 10478694].
29 De Bruyn G, Hahn S, Borwick A. Antibiotic treatment for travellers' diarrhoea. Cochrane Database of Systematic Reviews 2000;(3):Other.
30 Dear K, Holden J, Andrews R et al. Vaccines for preventing pneumococcal infection in adults. Cochrane Database of Systematic Reviews 2003;(4). Overlap with earlier SR on same topic.
31 Desai AS, Fang JC, Maisel WH, et al. Implantable defibrillators for the prevention of mortality in patients with nonischemic cardiomyopathy: a meta-analysis of randomized controlled trials. JAMA. 2004;292:2874-9. Overlap with earlier SR on same topic. [pmid: 15598919].
32 Di Blasi Z, Harkness E, Ernst E, et al. Influence of context effects on health outcomes: a systematic review. Lancet. 2001;357:757-62. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 11253970].
33 Dick PT. Canadian Task, Force on, et al. Periodic health examination, 1996 update: 1 Prenatal screening for and diagnosis of Down syndrome. Can Med Assoc J. 1996;154(4):465-79. Review of a non-therapeutic topic. [pmid: 8630836]. [pmcid: 1487598].
34 Dickson R, Fullerton D, Eastwood A, et al. Preventing and reducing the adverse effects of unintended teenage pregnancies. Effective Health Care. 1997;3(1):12. Focused on ineligible therapy.
35 Dimmock PW, Wyatt KM, Jones PW, et al. Efficacy of selective serotonin-reuptake inhibitors in premenstrual syndrome: a systematic review. Lancet. 2000;356:1131-6. Ineligible outcome format. [pmid: 11030291].
36 Dinnes J, Kleijnen J, Leitner M et al. Cardiac rehabilitation. Health Care 1999;865–71. Not clinical benefit or harm of a specific (class of) drug, device or procedure.
37 Dodds CS. Interventions for treating headlice. Cochrane Database of Systematic Reviews 2000;(2):Focused on ineligible therapy.
38 Dolovich LR, Ginsberg JS, Douketis JD, et al. A meta-analysis comparing low-molecular-weight heparins with unfractionated heparin in the treatment of venous thromboembolism : examining some unanswered questions regarding location of treatment, product type, and dosing frequency. Arch Intern Med. 2000;160:181-8. Overlap with earlier SR on same topic. [pmid: 10647756].
39 Doody RS, Stevens JC, Beck C. Practice parameter: management of dementia (an evidence-based review) : report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 2001;56:1154-66. Focused on ineligible therapy. [pmid: 11342679].
40 Douketis JD, Feightner JW, Attia J, et al. Periodic health examination, 1999 update: 1 Detection, prevention and treatment of obesity. CMAJ. 1999;160:513-25. Focused on ineligible therapy. [pmid: 10081468]. [pmcid: 1230077].
41 D'Souza AL, Rajkumar C, Cooke J, et al. Probiotics in prevention of antibiotic associated diarrhoea: meta-analysis. BMJ. 2002;324:1361-4. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 12052801]. [pmcid: 115209].
42 Ducharme F, Schwartz Z, Hicks G et al. Addition of anti-leukotriene agents to inhaled corticosteroids for chronic asthma. Cochrane Database of Systematic Reviews 2004;(2). Overlap with earlier SR on same topic.
43 Duley L, Henderson-Smart D J. Drugs for treatment of very high blood pressure during pregnancy. Cochrane Database of Systematic Reviews 2002;(4):Focused on ineligible therapy.
44 Duley L, Henderson-Smart D, Knight M, et al. Antiplatelet drugs for prevention of pre-eclampsia and its consequences: systematic review. BMJ. 2001;322:329-33. Overlap with earlier SR on same topic. [pmid: 11159655]. [pmcid: 26574].
45 Dusseldorp E, van Elderen T, Maes S, et al. A meta-analysis of psychoeducational programs for coronary heart disease patients. Health Psychol. 1999;18:506-19. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 10519467].
46 Eakin EG, Glasgow RE, Riley KM. Review of primary care-based physical activity intervention studies : effectiveness and implications for practice and future research. J Fam Pract. 2000;49:158-68. Focused on ineligible therapy. [pmid: 10718694].
47 Early Breast, Cancer Trialists', Collaborative Group. Effects of chemotherapy and hormonal therapy for early breast cancer on recurrence and 15-year survival: an overview of the randomised trials. Lancet. 2005;365:1687-717. Focused on ineligible therapy. [pmid: 15894097].
48 Ebrahim S, Davey Smith G. Multiple risk factor interventions for primary prevention of coronary heart disease. Cochrane Database of Systematic Reviews 1999;Not clinical benefit or harm of a specific (class of) drug, device or procedure.
49 Edmonds ML, Camargo CA, Pollack CV, et al. The effectiveness of inhaled corticosteroids in the emergency department treatment of acute asthma: a meta-analysis. Ann Emerg Med. 2002;40:145-54. Overlap with earlier SR on same topic. [pmid: 12140492].
50 Edwards A, Unigwe S, Elwyn G, et al. Effects of communicating individual risks in screening programmes: Cochrane systematic review. BMJ. 2003;327:703-9. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 14512475]. [pmcid: 200799].
51 Egger M, Davey Smith G, Stettler C, et al. Risk of adverse effects of intensified treatment in insulin-dependent diabetes mellitus: a meta-analysis. Diabet Med. 1997;14(11):919-28. Ineligible MA type. [pmid: 9400915].
52 Eisenberger MA, Blumenstein BA, Crawford ED. Bilateral orchiectomy with or without flutamide for metastatic prostate cancer. N Engl J Med. 1998;339:1036-42. Not an SR. [pmid: 9761805].
53 Ernst E. Chelation therapy for peripheral arterial occlusive disease: a systematic review. Circulation. 1997;96(3):1031-3. No MA for outcome in abstract. [pmid: 9264515].
54 Ernst E. The risk-benefit profile of commonly used herbal therapies: ginkgo, St John's wort, ginseng, echinacea, saw palmetto, and kava. Ann Intern Med. 2002;136:42-53. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 11777363].
55 Feder G, Cryer C, Donovan S, et al. Guidelines for the prevention of falls in people over 65. BMJ. 2000;321:1007-11. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 11039974]. [pmcid: 1118778].
56 Fendrick AM, Chernew ME, Hirth RA, et al. Alternative management strategies for patients with suspected peptic ulcer disease. Ann Intern Med. 1995;123(4):260-8. Not an SR. [pmid: 7611591].
57 Ferguson JA, Weinberger M. Case management programs in primary care. J Gen Intern Med. 1998;13:123-6. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 9502373]. [pmcid: 1496915].
58 Fiscella K, Franks P. Cost-effectiveness of the transdermal nicotine patch as an adjunct to physicians' smoking cessation counseling. JAMA. 1996;275(16):1247-51. Not an SR. [pmid: 8601956].
59 Fleming C, Whitlock EP, Beil TL, et al. Screening for abdominal aortic aneurysm: a best-evidence systematic review for the U.S : preventive Services Task Force. Ann Intern Med. 2005;142:203-11. Review of a non-therapeutic topic. [pmid: 15684209].
60 Fleming M F, Mundt M P, French M T. Brief physician advice for problem drinkers: long-term efficacy and benefit-cost analysis. Alcohol Clin Exp Res 2002;2636–43. Not an SR.
61 Ford AC, Qume M, Moayyedi P. Helicobacter pylori “test and treat” or endoscopy for managing dyspepsia: an individual patient data meta-analysis. Gastroenterology. 2005;128:1838-44. Ineligible MA type. [pmid: 15940619].
62 Forster A, Young J, Langhorne P, et al. Systematic review of day hospital care for elderly people. BMJ. 1999;318:837-41. Focused on ineligible therapy. [pmid: 10092260]. [pmcid: 27797].
63 Fraser W D, Krauss I, Brisson-Carrol G et al. Amniotomy to shorten spontaneous labour. Cochrane Database of Systematic Reviews 1995;(2):Date of original could not be established.
64 Friedrich JO, Adhikari N, Herridge MS, et al. Meta-analysis: low-dose dopamine increases urine output but does not prevent renal dysfunction or death. Ann Intern Med. 2005;142:510-24. Search date too recent (2005). [pmid: 15809463].
65 Gage BF, Cardinalli AB, Albers GW, et al. Cost-effectiveness of warfarin and aspirin for prophylaxis of stroke in patients with nonvalvular atrial fibrillation. JAMA. 1995;274(23):1839-45. Not an SR. [pmid: 7500532].
66 Garbutt JC, West SL, Carey TS, et al. Pharmacological treatment of alcohol dependence : a review of the evidence. JAMA. 1999;281:1318-25. Focused on ineligible therapy. [pmid: 10208148].
67 Gardlund B, for the, Heparin Prophylaxis et al. Randomised, controlled trial of low-dose heparin for prevention of fatal pulmonary embolism in patients with infectious diseases. Lancet 1996;347(9012):1357–61. Not an SR.
68 Gardner AW, Poehlman ET. Exercise rehabilitation programs for the treatment of claudication pain: A meta-analysis. JAMA. 1995;274(12):975-80. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 7674529].
69 Garner P, Gulmezoglu A M. Routine antimalarial drug chemoprophylaxis during pregnancy in endemic malarious areas. Cochrane Database of Systematic Reviews 1996;No MA for outcome in abstract.
70 Gaster B, Hirsch IB. The effects of improved glycemic control on complications in type 2 diabetes. Arch Intern Med. 1998;158:134-40. Focused on ineligible therapy. [pmid: 9448551].
71 Gelber RD, Cole BF, Goldhirsch A. Adjuvant chemotherapy plus tamoxifen compared with tamoxifen alone for postmenopausal breast cancer: meta-analysis of quality-adjusted survival. Lancet. 1996;347(9008):1066-71. Focused on ineligible therapy. [pmid: 8602056].
72 Gerstmann DR, Minton SD, Stoddard RA. The Provo Multicenter Early High-frequency Oscillatory Ventilation Trial: improved pulmonary and clinical outcome in respiratory distress syndrome. Pediatrics. 1996;98(6 Pt 1):1044-57. Not an SR. [pmid: 8951252].
73 Gibson P G, Coughlan J, Abramson M. The effects of self-management education and regular practitioner review in adults with asthma. Cochrane Database of Systematic Reviews 1998;Not clinical benefit or harm of a specific (class of) drug, device or procedure.
74 Gibson P G, Coughlan J, Wilson A J. The effects of limited (information only) patient education programs on the health outcomes of adults with asthma. Cochrane Database of Systematic Reviews 1998;1UpdateNot clinical benefit or harm of a specific (class of) drug, device or procedure.
75 Gibson P G, Henry R L, Coughlan J L. The effect of treatment for gastro-oesophageal reflux on asthma in adults and children. Cochrane Database of Systematic Reviews 1999;Focused on ineligible therapy.
76 Gibson P G, Powell H. Written action plans for asthma: an evidence-based review of the key components. Thorax 2004;5994–9. Not clinical benefit or harm of a specific (class of) drug, device or procedure.
77 Gill D, Hatcher S. A systematic review of the treatment of depression with antidepressant drugs in patients who also have a physical illness. Cochrane Database of Systematic Reviews 1998;Date of original could not be established.
78 Gillespie L D, Gillespie W J, Cumming R et al. Interventions to reduce the incidence of falling in the elderly. Cochrane Database of Systematic Reviews 1998;(1):Focused on ineligible therapy.
79 Glaser R, Herrmann HC, Murphy SA. Benefit of an early invasive management strategy in women with acute coronary syndromes. JAMA. 2002;288:3124-9. Not an SR. [pmid: 12495392].
80 Glasziou PP, Woodward AJ, Mahon CM. Mammographic screening trials for women aged under 50 : a quality assessment and meta-analysis. Med J Aust. 1995;162(12):625-9. Review of a non-therapeutic topic. [pmid: 7603372].
81 Glennie J, for the, Canadian Coordinating et al. The efficacy of tacrine and the measurement of outcomes in Alzheimer's Disease. CCOHTA Technology Overview: Pharmaceuticals 1997;5No MA for outcome in abstract.
82 Gloaguen V, Cottraux J, Cucherat M, et al. A meta-analysis of the effects of cognitive therapy in depressed patients. J Affect Disord. 1998;49:59-72. Focused on ineligible therapy. [pmid: 9574861].
83 Golden RN, Gaynes BN, Ekstrom RD. The efficacy of light therapy in the treatment of mood disorders: a review and meta-analysis of the evidence. Am J Psychiatry. 2005;162(4):656-62. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 15800134].
84 Gorelick PB, Sacco RL, Smith DB. Prevention of a first stroke : a review of guidelines and a multidisciplinary consensus statement from the National Stroke Association. JAMA. 1999;281:1112-20. Focused on ineligible therapy. [pmid: 10188663].
85 Gotzsche PC, Hammarquist C, Burr M. House dust mite control measures in the management of asthma: meta-analysis. BMJ. 1998;317:1105-10. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 9784442]. [pmcid: 28691].
86 Gotzsche PC, Johansen HK. Meta-analysis of short term low dose prednisolone versus placebo and non-steroidal anti-inflammatory drugs in rheumatoid arthritis. BMJ. 1998;316:811-8. Ineligible outcome format. [pmid: 9549450]. [pmcid: 28482].
87 Gotzsche P C, Johansen H K. Routine versus selective antifungal administration for control of fungal infections in patients with cancer. Cochrane Database of Systematic Reviews 2002;(2). Overlap with earlier SR on same topic.
88 Gotzsche P C. Somatostatin analogues for acute bleeding oesophageal varices. Cochrane Database of Systematic Reviews 2002;(1). Overlap with earlier SR on same topic.
89 Grossman E, Messerli FH, Goldbourt U. High blood pressure and diabetes mellitus : are all anti-hypertensive drugs created equal?. Arch Intern Med. 2000;160:2447-52. Focused on ineligible therapy. [pmid: 10979055].
90 Gueyffier F, Bulpitt C, Boissel JP. Antihypertensive drugs in very old people: a subgroup meta-analysis of randomised controlled trials. Lancet. 1999;353:793-6. Ineligible MA type. [pmid: 10459960].
91 Hacke W, Kaste M, Fieschi C, et al. Randomised double-blind placebo-controlled trial of thrombolytic therapy with intravenous alteplase in acute ischaemic stroke (ECASS II). Lancet. 1998;352:1245-51. Not an SR. [pmid: 9788453].
92 Haeusler G, Leitich H, van Trotsenburg M, et al. Drug therapy of urinary urge incontinence: a systematic review. Obstet Gynecol. 2002;100:1003-16. Focused on ineligible therapy. [pmid: 12423868].
93 Handoll H H, Madhok R. Surgical interventions for treating distal radial fractures in adults. Cochrane Database of Systematic Reviews 2001;CD003209. Focused on ineligible therapy.
94 Hankey G J, Sudlow C L, Dunbabin D W. Thienopyridine derivatives (ticlopidine, clopidogrel) versus aspirin for preventing stroke and other serious vascular events in high vascular risk patients. Cochrane Database of Systematic Reviews 1999.Overlap with earlier SR on same topic.
95 Hardy M, Coulter I, Morton S C. S-adenosyl-L-methionine for treatment of depression, osteoarthritis, and liver disease. Evid Rep Technol Assess (Summ) 2002;(Oct.):Not clinical benefit or harm of a specific (class of) drug, device or procedure.
96 Hatala R, Dinh T, Cook DJ. Once-daily aminoglycoside dosing in immunocompetent adults: a meta-analysis. Ann Intern Med. 1996;124(8):717-25. Overlap with earlier SR on same topic. [pmid: 8633831].
97 Hayden M, Pignone M, Phillips C, et al. Aspirin for the primary prevention of cardiovascular events: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;136:161-72. Overlap with earlier SR on same topic. [pmid: 11790072].
98 Hazell P, O'Connell D, Heathcote D, et al. Efficacy of tricyclic drugs in treating child and adolescent depression: a meta-analysis. BMJ. 1995;310(6984):897-901. Ineligible outcome format. [pmid: 7719178]. [pmcid: 2549288].
99 Hebert PR, Gaziano JM, Chan KS, et al. Cholesterol lowering with statin drugs, risk of stroke, and total mortality. An overview of randomized trials. JAMA. 1997;278:313-21. Overlap with earlier SR on same topic. [pmid: 9228438].
100 Herxheimer A, Petrie K J. Melatonin for preventing and treating jet lag. Cochrane Database of Systematic Reviews 2001;(1):Date of original could not be established.
101 Hochberg MC, Tracy JK, Flores RH. “Stepping-up” from methotrexate: a systematic review of randomised placebo controlled trials in patients with rheumatoid arthritis with an incomplete response to methotrexate. Ann Rheum Dis. 2001;60:iii51-iii54. Focused on ineligible therapy. [pmid: 11890654].
102 Hodnett E D. Home-like versus conventional institutional settings for birth. Cochrane Database of Systematic Reviews 2000;(2):Not clinical benefit or harm of a specific (class of) drug, device or procedure.
103 Hooper L, Brown T J, Elliott R. The effectiveness of five strategies for the prevention of gastrointestinal toxicity induced by non-steroidal anti-inflammatory drugs: systematic review. BMJ 2004;329948Focused on ineligible therapy.
104 Hotopf M, Lewis G, Normand C. Are SSRIs a cost-effective alternative to tricyclics?. Br J Psychiatry. 1996;168(4):404-9. Review of a non-therapeutic topic. [pmid: 8730935].
105 Hrobjartsson A, Gotzsche PC. Is the placebo powerless? An analysis of clinical trials comparing placebo with no treatment. N Engl J Med. 2001;344:1594-602. Focused on ineligible therapy. [pmid: 11372012].
106 Huang ES, Meigs JB, Singer DE. The effect of interventions to prevent cardiovascular disease in patients with type 2 diabetes mellitus. Am J Med. 2001;111:633-42. Focused on ineligible therapy. [pmid: 11755507].
107 Hughes RA, Wijdicks EF, Barohn R. Practice parameter: Immunotherapy for Guillain-Barre syndrome: Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 2003;61:736-40. Focused on ineligible therapy. [pmid: 14504313].
108 Hull RD, Pineo GF, Stein PD. Extended out-of-hospital low-molecular-weight heparin prophylaxis against deep venous thrombosis in patients after elective hip arthroplasty: a systematic review. Ann Intern Med. 2001;135:858-69. Overlap with earlier SR on same topic. [pmid: 11712876].
109 Hull RD, Raskob GE, Brant RF, et al. Low-molecular-weight heparin vs heparin in the treatment of patients with pulmonary embolism. Arch Intern Med. 2000;160:229-36. Not an SR. [pmid: 10647762].
110 Humphrey LL, Chan BK, Sox HC. Postmenopausal hormone replacement therapy and the primary prevention of cardiovascular disease. Ann Intern Med. 2002;137:273-84. Non-RCTs included. [pmid: 12186518].
111 Humphrey LL, Helfand M, Chan BK, et al. Breast cancer screening: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137:347-60. Review of a non-therapeutic topic. [pmid: 12204020].
112 Hunt DL, Haynes RB, Hanna SE, et al. Effects of computer-based clinical decision support systems on physician performance and patient outcomes: A systematic review. JAMA. 1998;280:1339-46. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 9794315].
113 Huntley A, Ernst E. Herbal medicines for asthma: a systematic review. Thorax. 2000;55:925-9. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 11050261]. [pmcid: 1745625].
114 Indredavik B, Bakke F, Slordahl SA, et al. Stroke unit treatment improves long-term quality of life: A randomized controlled trial. Stroke. 1998;29:895-9. Not an SR. [pmid: 9596231].
115 Indredavik B, Slordahl SA, Bakke F, et al. Stroke unit treatment. Long-term effects. Stroke. 1997;28:1861-6. Not an SR. [pmid: 9341685].
116 Ioannidis JP, Cappelleri JC, Skolnik PR, et al. A meta-analysis of the relative efficacy and toxicity of Pneumocystis carinii prophylactic regimens. Arch Intern Med. 1996;156(2):177-88. Focused on ineligible therapy. [pmid: 8546551].
117 Ioannidis JP, Lau J. Evidence on interventions to reduce medical errors. An overview and recommendations for future research. J Gen Intern Med. 2001;16:325-34. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 11359552]. [pmcid: 1495210].
118 Jadad A R, Boyle M, Cunningham C et al. Treatment of attention-deficit/hyperactivity disorder. Evid Rep Technol Assess (Summ) 1999;1–341. Focused on ineligible therapy.
119 Jafar TH, Schmid CH, Landa M, et al. Angiotensin-converting enzyme inhibitors and progression of nondiabetic renal disease. A meta-analysis of patient-level data. Ann Intern Med. 2001;13:573-87. Ineligible MA type.
120 Jailwala J, Imperiale TF, Kroenke K. Pharmacologic treatment of the irritable bowel syndrome: a systematic review of randomized, controlled trials. Ann Intern Med. 2000;133:136-47. Focused on ineligible therapy. [pmid: 10896640].
121 Jewell D, Young G. Interventions for nausea and vomiting in early pregnancy. Cochrane Database of Systematic Reviews 2002;(1):Focused on ineligible therapy.
122 Johnson ES, Lanes SF, Wentworth CE. A metaregression analysis of the dose-response effect of aspirin on stroke. Arch Intern Med. 1999;159:1248-53. Ineligible MA type. [pmid: 10371234].
123 Jones A, Fay J K, Burr M. Inhaled corticosteroid effects on bone metabolism in asthma and mild chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews 2002;(1):Summary statistic was continuous, not WMD.
124 Jones G, Halbert J, Crotty M. The effect of treatment on radiological progression in rheumatoid arthritis: a systematic review of randomized placebo-controlled trials. Rheumatology. 2003;42(6):13. Focused on ineligible therapy.
125 Julian DG, Camm AJ, Frangin G, et al. Randomised trial of effect of amiodarone on mortality in patients with left-ventricular dysfunction after recent myocardial infarction: EMIAT. Lancet. 1997;349:667-74. Not an SR. [pmid: 9078197].
126 Jung AC, Staiger T, Sullivan M. The efficacy of selective serotonin reuptake inhibitors for the management of chronic pain. J Gen Intern Med. 1997;12:384-9. No MA for outcome in abstract. [pmid: 9192257]. [pmcid: 1497123].
127 Kahan M, Wilson L, Becker L. Effectiveness of physician-based interventions with problem drinkers: a review. CMAJ. 1995;152(6):851-9. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 7697578]. [pmcid: 1337758].
128 Katlama C, Ingrand D, Loveday C, et al. Safety and efficacy of lamivudine-zidovudine combination therapy in antiretroviral-naive patients. A randomized controlled comparison with zidovudine monotherapy. JAMA. 1996;276(2):118-25. Not an SR. [pmid: 8656503].
129 Kattlove H, Liberati A, Keeler E, et al. Benefits and costs of screening and treatment for early breast cancer : development of a basic benefit package. JAMA. 1995;273(2):142-8. Review of a non-therapeutic topic. [pmid: 7799495].
130 Kaushal R, Shojania KG, Bates DW. Effects of computerized physician order entry and clinical decision support systems on medication safety: a systematic review. Arch Intern Med. 2003;163:1409-16. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 12824090].
131 Kearon C, Hirsh J. Starting prophylaxis for venous thromboembolism postoperatively. Arch Intern Med. 1995;155(4):366-372. Focused on ineligible therapy. [pmid: 7848019].
132 Keeley EC, Boura JA, Grines CL. Primary angioplasty versus intravenous thrombolytic therapy for acute myocardial infarction: a quantitative review of 23 randomised trials. Lancet. 2003;361:13-20. Overlap with earlier SR on same topic. [pmid: 12517460].
133 Keenan SP, Sinuff T, Cook DJ, et al. Does noninvasive positive pressure ventilation improve outcome in acute hypoxemic respiratory failure? A systematic review. Crit Care Med. 2004;32:2516-23. Overlap with earlier SR on same topic. [pmid: 15599160].
134 Kenyon SL, Taylor DJ, Tarnow-Mordi W, et al. Broad-spectrum antibiotics for preterm, prelabour rupture of fetal membranes: the ORACLE I randomised trial. Lancet. 2001;357:979-88. Not an SR. [pmid: 11293640].
135 Kenyon SL, Taylor DJ, Tarnow-Mordi W, et al. Broad-spectrum antibiotics for spontaneous preterm labour: the ORACLE II randomised trial. Lancet. 2001;357:989-94. Not an SR. [pmid: 11293641].
136 Kerlikowske K, Grady D, Rubin SM, et al. Efficacy of screening mammography: A meta-analysis. JAMA. 1995;273(2):149-54. Review of a non-therapeutic topic. [pmid: 7799496].
137 Kleijnen J, Mackerras D. Vitamin E for the treatment of intermittent claudication. Cochrane Database of Systematic Reviews 1998;(1). UpdateUnneeded Cochrane review.
138 Ko DT, Hebert PR, Coffey CS. Adverse effects of [beta]-blocker therapy for patients with heart failure: a quantitative overview of randomized trials. Arch Intern Med. 2004;164:1389-94. Overlap with earlier SR on same topic. [pmid: 15249347].
139 Kolbach D N, Sandbrink M W, Hamulyak K et al. Non-pharmaceutical measures for prevention of post-thrombotic syndrome. Cochrane Database of Systematic Reviews 2004;(1). Unneeded Cochrane review.
140 Kronenberg F, Fugh-Berman A. Complementary and alternative medicine for menopausal symptoms: a review of randomized, controlled trials. Ann Intern Med. 2002;137:805-13. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 12435217].
141 Krueger WA, Lenhart FP, Neeser G. Influence of combined intravenous and topical antibiotic prophylaxis on the incidence of infections, organ dysfunctions, and mortality in critically ill surgical patients: a prospective, stratified, randomized, double-blind, placebo-controlled clinical trial. Am J Respir Crit Care Med. 2002;166:1029-37. Not an SR. [pmid: 12379544].
142 Krystal JH, Cramer JA, Krol WF, et al. Naltrexone in the treatment of alcohol dependence. N Engl J Med. 2001;345:1734-9. Not an SR. [pmid: 11742047].
143 Kwan J, Sandercock P. In-hospital care pathways for stroke. Cochrane Database of Systematic Reviews 2002;(2). Focused on ineligible therapy.
144 Lancaster T, Stead L, Silagy C, et al. Effectiveness of interventions to help people stop smoking: findings from the Cochrane Library. BMJ. 2000;321:355-8. Focused on ineligible therapy. [pmid: 10926597]. [pmcid: 1118332].
145 Langhorne P, Taylor G, Murray G. Early supported discharge services for stroke patients: a meta-analysis of individual patients' data. Lancet. 2005;365:501-6. Focused on ineligible therapy. [pmid: 15705460].
146 Law M, Tang JL. An analysis of the effectiveness of interventions intended to help people stop smoking. Arch Intern Med. 1995;155(18):1933-41. Focused on ineligible therapy. [pmid: 7575046].
147 Lechat P, Packer M, Chalon S. Clinical effects of [beta]-adrenergic blockade in chronic heart failure: A meta-analysis of double-blind, placebo-controlled, randomized trials. Circulation. 1998;98:1184-91. Overlap with earlier SR on same topic. [pmid: 9743509].
148 Lee A, Cooper M G, Craig J C et al. Effects of nonsteroidal anti-inflammatory drugs on post-operative renal function in adults. Cochrane Database of Systematic Reviews 2001;(2):Unneeded Cochrane review.
149 Lees AJ, Katzenschlager R, Head J, et al. Ten-year follow-up of three different initial treatments in denovo PD: A randomized trial. Neurology. 2001;57:1687-94. Not an SR. [pmid: 11706112].
150 Leonardi-Bee J, Bath PM, Bousser MG. Dipyridamole for preventing recurrent ischemic stroke and other vascular events: a meta-analysis of individual patient data from randomized controlled trials. Stroke. 2005;36:162-8. Ineligible MA type. [pmid: 15569877].
151 Levine C B, Fahrbach K R, Siderowf A D. Diagnosis and treatment of Parkinson's disease: a systematic review of the literature. Evid Rep Technol Assess (Summ) 2003;571–4. Summary statistic was continuous, not WMD.
152 Levine RJ, Hauth JC, Curet LB. Trial of calcium to prevent pre-eclampsia. N Engl J Med. 1997;337:69-76. Not an SR. [pmid: 9211675].
153 Lewin S A, Skea Z C, Entwistle V et al. Interventions for providers to promote a patient-centred approach in clinical consultations. Cochrane Database of Systematic Reviews 2001;(4):Not clinical benefit or harm of a specific (class of) drug, device or procedure.
154 Li Z, Maglione M, Tu W. Meta-analysis: pharmacologic treatment of obesity. Ann Intern Med. 2005;142:532-46. Focused on ineligible therapy. [pmid: 15809465].
155 Linden W, Stossel C, Maurice J. Psychosocial interventions for patients with coronary artery disease: A meta-analysis. Arch Intern Med. 1996;156(7):745-52. Focused on ineligible therapy. [pmid: 8615707].
156 Liver Infusion, Meta-analysis Group. Portal vein chemotherapy for colorectal cancer: a meta-analysis of 4000 patients in 10 studies. J Natl Cancer Inst. 1997;89:497-505. Ineligible MA type. [pmid: 9086006].
157 Low DE, Desrosiers M, McSherry J. A practical guide for the diagnosis and treatment of acute sinusitis. CMAJ. 1997;156(Suppl. 6):1S-14S. Focused on ineligible therapy.
158 ls-Nielsen B, Gluud L L, Gluud C. Nonabsorbable disaccharides for hepatic encephalopathy. Cochrane Database of Systematic Reviews 2004;(2). Unneeded Cochrane review.
159 Luria JW, Gonzalez-del-Rey JA, DiGiulio GA. Effectiveness of oral or nebulized dexamethasone for children with mild croup. Arch Pediatr Adolesc Med. 2001;155:1340-5. Not an SR. [pmid: 11732953].
160 Magee LA, Ornstein MP, von Dadelszen P. Management of hypertension in pregnancy. BMJ. 1999;318:1332-6. Focused on ineligible therapy. [pmid: 10323823]. [pmcid: 1115719].
161 Maggard MA, Shugarman LR, Suttorp M. Meta-analysis: surgical treatment of obesity. Ann Intern Med. 2005;142:547-59. Focused on ineligible therapy. [pmid: 15809466].
162 Manser RL, Irving LB, Byrnes G. Screening for lung cancer: a systematic review and meta-analysis of controlled trials. Thorax. 2003;58:784-9. Review of a non-therapeutic topic. [pmid: 12947138]. [pmcid: 1746815].
163 Man-Son-Hing M, Wells G. Meta-analysis of efficacy of quinine for treatment of nocturnal leg cramps in elderly people. BMJ. 1995;310(6971):13-7. Ineligible MA type. [pmid: 7827545]. [pmcid: 2548434].
164 Marshall J K, Blackhouse G, Goeree R. Infliximab for the treatment of Crohn's disease: a systematic review and cost-utility analysis. Evid Rep Technol Assess (Summ) 2002;No MA for outcome in abstract.
165 Martin-Hirsch P, Lilford R, Jarvis G, et al. Efficacy of cervical-smear collection devices: a systematic review and meta-analysis. Lancet. 1999;354:1763-70. Review of a non-therapeutic topic. [pmid: 10577637].
166 Mason J, O'Keeffe C, McIntosh A. A systematic review of foot ulcer in patients with type 2 diabetes mellitus : I: Prevention; II: Treatment. Diabet Med. 1999;16:801-12. Focused on ineligible therapy. [pmid: 10547206].
167 Mayo-Smith MF, Beecher LH, Fischer TL. Management of alcohol withdrawal delirium: an evidence-based practice guideline. Arch Intern Med. 2004;164:1405-12. Focused on ineligible therapy. [pmid: 15249349].
168 Mayo-Smith M F, for the, American Society et al. Pharmacological management of alcohol withdrawal: A meta-analysis and evidence-based practice guideline. JAMA 1997;278:144–51. Focused on ineligible therapy.
169 McAlindon TE, LaValley MP, Gulin JP, et al. Glucosamine and chondroitin for treatment of osteoarthritis: a systematic quality assessment and meta-analysis. JAMA. 2000;283:1469-75. Ineligible outcome format. [pmid: 10732937].
170 McAlister FA, Ezekowitz JA, Wiebe N. Systematic review: cardiac resynchronization in patients with symptomatic heart failure. Ann Intern Med. 2004;141:381-90. Overlap with earlier SR on same topic. [pmid: 15353430].
171 McAlister FA, Lawson FM, Teo KK, et al. Randomised trials of secondary prevention programmes in coronary heart disease: systematic review. BMJ. 2001;323:957-62. Focused on ineligible therapy. [pmid: 11679383]. [pmcid: 58658].
172 McCartney P, Macdowall W, Thorogood M. A randomised controlled trial of feedback to general practitioners of their prophylactic aspirin prescribing. BMJ. 1997;315:35-6. Not an SR. [pmid: 9233326]. [pmcid: 2127027].
173 McCrory D C, Brown C D. Anti-cholinergic bronchodilators versus beta2-sympathomimetic agents for acute exacerbations of chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews 2002;(4):Unneeded Cochrane review.
174 McCusker J, Cole M, Keller E, et al. Effectiveness of treatments of depression in older ambulatory patients. Arch Intern Med. 1998;158:705-12. Focused on ineligible therapy. [pmid: 9554676].
175 McDermott MM, Schmitt B, Wallner E. Impact of medication nonadherence on coronary heart disease outcomes: a critical review. Arch Intern Med. 1997;157:1921-9. Review of a non-therapeutic topic. [pmid: 9308504].
176 McDonald HP, Garg AX, Haynes RB. Interventions to enhance patient adherence to medication prescriptions: scientific review. JAMA. 2002;288:2868-79. Review of a non-therapeutic topic. [pmid: 12472329].
177 McLeod RS, members of, the Canadian et al. Screening strategies for colorectal cancer: a systematic review of the evidence. Can J Gastroenterol 2001;15:647–60. Review of a nontherapeutic topic.
178 McQuay HJ. Pre-emptive analgesia: a systematic review of clinical studies. Ann Med. 1995;27(2):249-56. Focused on ineligible therapy. [pmid: 7632422].
179 Mehta SR, Yusuf S, Diaz R. Effect of glucose-insulin-potassium infusion on mortality in patients with acute ST-segment elevation myocardial infarction: the CREATE-ECLA randomized controlled trial. JAMA. 2005;293:437-46. Not an SR. [pmid: 15671428].
180 MERIT-HF Study, Group. Effect of metoprolol CR/XL in chronic heart failure: Metoprolol CR/XL Randomised Intervention Trial in Congestive Heart Failure (MERIT-HF). Lancet. 1999;353:2001-7. Not an SR. [pmid: 10376614].
181 Merkel C, Marin R, Enzo E, et al. Randomised trial of nadolol alone or with isosorbide mononitrate for primary prophylaxis of variceal bleeding in cirrhosis. Lancet. 1996;348(9043):1677-81. Not an SR. [pmid: 8973428].
182 Mermel LA. Prevention of intravascular catheter-related infections. Ann Intern Med. 2000;132:391-402. Review of a non-therapeutic topic. [pmid: 10691590].
183 Messerli FH, Grossman E, Goldbourt U. Are [beta]-blockers efficacious as first-line therapy for hypertension in the elderly? A systematic review. JAMA. 1998;279:1903-7. Unneeded Cochrane review. [pmid: 9634263].
184 Miller AB, To T, Baines CJ, et al. The Canadian National Breast Screening Study-1: breast cancer mortality after 11 to 16 years of follow up: A randomized screening trial of mammography in women age 40 to 49 years. Ann Intern Med. 2002;137:305-12. Not an SR. [pmid: 12204013].
185 Miller J, Chan BK, Nelson HD. Postmenopausal estrogen replacement and risk for venous thromboembolism: a systematic review and meta-analysis for the U.S Preventive Services Task Force. Ann Intern Med. 2002;136:680-90. Non-RCTs included. [pmid: 11992304].
186 Miller MR, McNamara RL, Segal JB. Efficacy of agents for pharmacologic conversion of atrial fibrillation and subsequent maintenance of sinus rhythm: A meta-analysis of clinical trials. J Fam Pract. 2000;49:1033-46. Focused on ineligible therapy. [pmid: 11093570].
187 Miller R G, Mitchell J D, Moore D H. Riluzole for amyotrophic lateral sclerosis (ALS)/motor neuron disease (MND). Cochrane Database of Systematic Reviews 1999;Date of original could not be established.
188 Milne S, Welch V, Brosseau L. Transcutaneous electrical nerve stimulation (TENS) for chronic low back pain. Cochrane Database of Systematic Reviews 2001;(2). Overlap with earlier SR on same topic.
189 Minneci PC, Deans KJ, Banks SM, et al. Meta-analysis: the effect of steroids on survival and shock during sepsis depends on the dose. Ann Intern Med. 2004;141:47-56. Overlap with earlier SR on same topic. [pmid: 15238370].
190 Miyasaki JM, Martin W, Suchowersky O, et al. Practice parameter: initiation of treatment for Parkinson's disease: an evidence-based review. Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 2002;58:11-7. No MA for outcome in abstract. [pmid: 11781398].
191 Moayyedi P, Delaney BC, Vakil N, et al. The efficacy of proton pump inhibitors in nonulcer dyspepsia: a systematic review and economic analysis. Gastroenterology. 2004;127:1329-37. Overlap with earlier SR on same topic. [pmid: 15521002].
192 Moore RA. Livial: a review of clinical studies. Br J Obstet Gynaecol. 1999;106(Suppl):1-21. Focused on ineligible therapy. [pmid: 10890791].
193 Morrison LJ, Verbeek PR, McDonald AC, et al. Mortality and prehospital thrombolysis for acute myocardial infarction: A meta-analysis. JAMA. 2000;283:2686-92. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 10819952].
194 Morrison RS, Chassin MR, Siu AL. The medical consultant's role in caring for patients with hip fracture. Ann Intern Med. 1998;128:1010-20. Focused on ineligible therapy. [pmid: 9625664].
195 Moyer A, Finney JW, Swearingen CE, et al. Brief interventions for alcohol problems: a meta-analytic review of controlled investigations in treatment-seeking and non-treatment-seeking populations. Addiction. 2002;97:279-92. Focused on ineligible therapy. [pmid: 11964101].
196 Mukherjee D, Nissen SE, Topol EJ. Risk of cardiovascular events associated with selective COX-2 inhibitors. JAMA. 2001;286:954-9. No MA for outcome in abstract. [pmid: 11509060].
197 Mullen PD, Simons-Morton DG, Ram'rez G. A meta-analysis of trials evaluating patient education and counseling for three groups of preventive health behaviors. Patient Educ Couns. 1997;32:157-73. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 9423498].
198 NHS Centre, for Reviews, Dissemination Nuffield, et al. Preventing falls and subsequent injury in older people. Eff Health Care. 1996;2:1-16. Focused on ineligible therapy.
199 Nista EC, Candelli M, Cremonini F. Levofloxacin-based triple therapy vs. quadruple therapy in second-line Helicobacter pylori treatment: a randomized trial. Aliment Pharmacol Ther. 2003;18:627-33. Not an SR. [pmid: 12969089].
200 Norris SL, Engelgau MM, Venkat Narayan KM. Effectiveness of self-management training in type 2 diabetes: A systematic review of randomized controlled trials. Diabetes Care. 2001;24:561-87. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 11289485].
201 Norris SL, Zhang X, Avenell A. Efficacy of pharmacotherapy for weight loss in adults with type 2 diabetes mellitus: a meta-analysis. Arch Intern Med. 2004;164:1395-404. Focused on ineligible therapy. [pmid: 15249348].
202 O'Brien B, Goeree R, Mohamed AH, et al. Cost-effectiveness of Helicobacter pylori eradication for the long-term management of duodenal ulcer in Canada. Arch Intern Med. 1995;155(18):1958-64. Review of a non-therapeutic topic. [pmid: 7575049].
203 O'Connor AM, Rostom A, Fiset V. Decision aids for patients facing health treatment or screening decisions: systematic review. BMJ. 1999;319:731-4. Not clinical benefit or harm of a specific (class of) drug, device or procedure. [pmid: 10487995]. [pmcid: 28223].
204 Ofman JJ, Rabeneck L. The effectiveness of endoscopy in the management of dyspepsia: a qualitative systematic review. Am J Med. 1999;106:335-46. Review of a non-therapeutic topic. [pmid: 10190384].
205 Oldman AD, Smith LA, McQuay HJ, et al. Pharmacological treatments for acute migraine: quantitative systematic review. Pain. 2002;97:247-57. Focused on ineligible therapy. [pmid: 12044621].
206 O'Mallcy PG, Balden E, Tomkins G. Treatment of fibromyalgia with antidepressants: A meta-analysis. J Gen Intern Med. 2000;15:659-66. Ineligible outcome format. [pmid: 11029681]. [pmcid: 1495596].
207 O'Malley PG, Jackson JL, Santoro J. Antidepressant therapy for unexplained symptoms and symptom syndromes. J Fam Pract. 1999;48:980-90. Ineligible outcome format. [pmid: 10628579].
208 O'Meara S M, Cullum N A, Majid M et al. Systematic review of antimicrobial agents used for chronic wounds. Br J Surg 2001;884–21. Focused on ineligible therapy.
209 Ostermann ME, Keenan SP, Seiferling RA, et al. Sedation in the intensive care unit: A systematic review. JAMA. 2000;283:1451-9. Focused on ineligible therapy. [pmid: 10732935].
210 Overgaard M, Hansen PS, Overgaard J, et al. Postoperative radiotherapy in high-risk premenopausal women with breast cancer who receive adjuvant chemotherapy. N Engl J Med. 1997;337:949-55. Not an SR. [pmid: 9395428].
211 Padwal R, Li S K, Lau D C. Long-term pharmacotherapy for obesity and overweight. Cochrane Database of Systematic Reviews 2004;(3):Focused on ineligible therapy.
212 Padwal R, Majumdar SR, Johnson JA, et al. A systematic review of drug therapy to delay or prevent type 2 diabetes. Diabetes Care. 2005;28:736-44. Focused on ineligible therapy. [pmid: 15735219].
213 Parameswaran K, Belda J, Rowe B H. Addition of intravenous aminophylline to beta2-agonists in adults with acute asthma. Cochrane Database of Systematic Reviews 2000;(4):Unneeded Cochrane review.
214 Paramothayan N S, Jones P W. Corticosteroids for pulmonary sarcoidosis. Cochrane Database of Systematic Reviews 2000;(1). Unneeded Cochrane review.
215 Parker M J, Handoll H H, Robinson C M. Gamma nail versus sliding hip screw for the treatment of extracapsular femoral fractures. Cochrane Database of Systematic Reviews 1996;(1):Date of original could not be established.
216 Parkes J, Shepperd S. Discharge planning from hospital to home. Cochrane Database of Systematic Reviews 2000;(4):Review of a non-therapeutic topic.
217 Peter JV, Moran JL, Phillips-Hughes J, et al. Noninvasive ventilation in acute respiratory failure-a meta-analysis update. Crit Care Med. 2002;30:555-62. Overlap with earlier SR on same topic. [pmid: 11990914].
218 Piccinelli M, Pini S, Bellantuono C, et al. Efficacy of drug treatment in obsessive-compulsive disorder: A meta-analytic review. Br J Psychiatry. 1995;166(4):424-43. Ineligible outcome format. [pmid: 7795913].
219 Pignone MP, Gaynes BN, Rushton JL. Screening for depression in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;136:765-76. Review of a non-therapeutic topic. [pmid: 12020146].
220 Pirozzo S, Summerbell C, Cameron C et al. Advice on low-fat diets for obesity. Cochrane Database of Systematic Reviews 2002;(2):Not clinical benefit or harm of a specific (class of) drug, device or procedure.
221 Pittler M H, Ernst E. Efficacy of kava extract for treating anxiety: systematic review and metaanalysis. J Clin Psychopharmacol 2000;2084–89. Not clinical benefit or harm of a specific (class of) drug, device or procedure.
222 PORT Meta-analysis, Trialists Group. Postoperative radiotherapy in non-small-cell lung cancer: systematic review and meta-analysis of individual patient data from nine randomised controlled trials. Lancet. 1998;352:257-63. Ineligible MA type. [pmid: 9690404].
223 Porthouse J, Cockayne S, King C. Randomised controlled trial of calcium and suplementation with cholecalciferol (vitamin D(subscript 3)) for prevention of fractures in primary care. BMJ. 2005;330:1003. Not an SR. 2005;3301003Not an SR. [pmid: 15860827]. [pmcid: 557150].