# References and Included Studies

## Cohort Meta-Analyses Sorted by Signals

### Primary signal for updating

#### Potentially invalidating qualitative signal (with or without quantitative signal)

1 Alderson P, Schierhout G, Roberts I, Bunn F. Colloids versus crystalloids for fluid resuscitation in critically ill patients. Cochrane Database Syst Rev. 2000(2):CD000567.
2 Alejandria MM, Lansang MA, Dans LF, Mantaring JB. Intravenous immunoglobulin for treating sepsis and septic shock. Cochrane Database Syst Rev. 2002(1):CD001090.
3 Bucher HC, Guyatt GH, Cook RJ, et al. Effect of calcium supplementation on pregnancy-induced hypertension and preeclampsia: a meta-analysis of randomized controlled trials. JAMA. 1996;275(14):1113-7. [pmid: 8601931].
4 Coward LJ, Featherstone RL, Brown MM. Safety and efficacy of endovascular treatment of carotid artery stenosis compared with carotid endarterectomy: a Cochrane systematic review of the randomized evidence. Stroke. 2005;36(4):905-11. [pmid: 15746454].
5 Hemminki E, McPherson K. Impact of postmenopausal hormone therapy on cardiovascular events and cancer: pooled data from clinical trials. BMJ. 1997;315(7101):149-53. [pmid: 9251544]. [pmcid: 2127109].
6 Kjaergard LL, Krogsgaard K, Gluud C. Interferon alfa with or without ribavirin for chronic hepatitis C: systematic review of randomised trials. BMJ. 2001;323(7322):1151-5. [pmid: 11711405]. [pmcid: 59848].
7 Lefering R, Neugebauer EA. Steroid controversy in sepsis and septic shock: a meta-analysis. Crit Care Med. 1995;23(7):1294-303. [pmid: 7600840].
8 Lord JM, Flight IH, Norman RJ. Metformin in polycystic ovary syndrome: systematic review and meta-analysis. BMJ. 2003;327(7421):951-3. [pmid: 14576245]. [pmcid: 259161].

#### Major signal for updating

9 Gotzsche PC, Johansen HK. Meta-analysis of prophylactic or empirical antifungal treatment versus placebo or no treatment in patients with cancer complicated by neutropenia. BMJ. 1997;314(7089):1238-14. [pmid: 9154027]. [pmcid: 2126615].
10 Abramson MJ, Puy RM, Weiner JM. Is allergen immunotherapy effective in asthma? A meta-analysis of randomized controlled trials. Am J Respir Crit Care Med. 1995;151(4):969-74. [pmid: 7697274].
11 Collaborative meta-analysis of randomised trials of antiplatelet therapy for prevention of death, myocardial infarction, and stroke in high risk patients. BMJ. 2002;324(7329):71–86.
12 Avezum A, Tsuyuki RT, Pogue J, Yusuf S. Beta-blocker therapy for congestive heart failure: a systemic overview and critical appraisal of the published trials. Can J Cardiol. 1998;14(8):1045-53. [pmid: 9738164].
13 Benavente O, Moher D, Pham B. Carotid endarterectomy for asymptomatic carotid stenosis: a meta-analysis. BMJ. 1998;317(7171):1477-80. [pmid: 9831572]. [pmcid: 28726].
14 Birck R, Krzossok S, Markowetz F, Schnulle P, van der Woude FJ, Braun C. Acetylcysteine for prevention of contrast nephropathy: meta-analysis. Lancet. 2003;362(9384):598-603. [pmid: 12944058].
15 Bischoff-Ferrari HA, Dawson-Hughes B, Willett WC, et al. Effect of Vitamin D on falls: a meta-analysis. JAMA. 2004;291(16):1999-2006. [pmid: 15113819].
16 Neal B, MacMahon S, Chapman N. Effects of ACE inhibitors, calcium antagonists, and other blood-pressure-lowering drugs: results of prospectively designed overviews of randomised trials. Blood Pressure Lowering Treatment Trialists' Collaboration. Lancet. 2000;356(9246):1955-64. [pmid: 11130523].
17 Blumenauer B, Judd M, Cranney A, et al. Etanercept for the treatment of rheumatoid arthritis. Cochrane Database Syst Rev. 2003(4):CD004525.
18 Bosch X, Marrugat J. Platelet glycoprotein IIb/IIIa blockers for percutaneous coronary revascularization, and unstable angina and non-ST-segment elevation myocardial infarction. Cochrane Database Syst Rev. 2001(4):CD002130.
19 Boucher M, McAuley L, Brown A, Keely E, Skidmore B. Efficacy of rosiglitazone and pioglitazone compared to other anti-diabetic agents: systematic review and budget impact analysis. . Ottawa: Canadian Coordinating Office for Health Technology Assessment. Technology report no 29. . 2002.
20 Brown DL, Fann CS, Chang CJ. Meta-analysis of effectiveness and safety of abciximab versus eptifibatide or tirofiban in percutaneous coronary intervention. Am J Cardiol. 2001;87(5):537-41. [pmid: 11230835].
21 Bucher HC, Griffith LE, Guyatt GH. Effect of HMGcoA reductase inhibitors on stroke. A meta-analysis of randomized, controlled trials. Ann Intern Med. 1998;128(2):89-95. [pmid: 9441587].
22 Bucher HC, Hengstler P, Schindler C, Guyatt GH. Percutaneous transluminal coronary angioplasty versus medical treatment for non-acute coronary heart disease: meta-analysis of randomised controlled trials. BMJ. 2000;321(7253):73-7. [pmid: 10884254]. [pmcid: 27425].
23 Carlberg B, Samuelsson O, Lindholm LH. Atenolol in hypertension: is it a wise choice?. Lancet. 2004;364(9446):1684-9. [pmid: 15530629].
24 Cody J, Daly C, Campbell M, et al. Recombinant human erythropoietin for chronic renal failure anaemia in pre-dialysis patients. Cochrane Database Syst Rev. 2005(3):CD003266.
25 Cranney A, Welch V, Adachi JD, et al. Etidronate for treating and preventing postmenopausal osteoporosis. Cochrane Database Syst Rev. 2001(4):CD003376.
26 Crouse JR 3rd, Byington RP, Hoen HM, Furberg CD. Reductase inhibitor monotherapy and stroke prevention. Arch Intern Med. 1997;157(12):1305-10. [pmid: 9201004].
27 Cullum N, McInnes E, Bell-Syer SE, Legood R. Support surfaces for pressure ulcer prevention. Cochrane Database Syst Rev. 2004(3):CD001735.
28 D'Amico R, Pifferi S, Leonetti C, Torri V, Tinazzi A, Liberati A. Effectiveness of antibiotic prophylaxis in critically ill adult patients: systematic review of randomised controlled trials. BMJ. 1998;316(7140):1275-85. [pmid: 9554897].
29 Ng D, Salvio F, Hicks G. Anti-leukotriene agents compared to inhaled corticosteroids in the management of recurrent and/or chronic asthma in adults and children. Cochrane Database Syst Rev. 2004(2):CD002314.
30 Effects of radiotherapy and surgery in early breast cancer. An overview of the randomized trials. Early Breast Cancer Trialists' Collaborative Group. N Engl J Med. 1995;333(22):1444–55.
31 Etminan M, Levine MA, Tomlinson G, Rochon PA. Efficacy of angiotensin II receptor antagonists in preventing headache: a systematic overview and meta-analysis. Am J Med. 2002;112(8):642-6. [pmid: 12034414].
32 Evans BW, Clark WK, Moore DJ, Whorwell PJ. Tegaserod for the treatment of irritable bowel syndrome. Cochrane Database Syst Rev. 2004(1):CD003960.
33 Ezekowitz JA, Armstrong PW, McAlister FA. Implantable cardioverter defibrillators in primary and secondary prevention: a systematic review of randomized, controlled trials. Ann Intern Med. 2003;138(6):445-52. [pmid: 12639076].
34 Fahey T, Stocks N, Thomas T. Quantitative systematic review of randomised controlled trials comparing antibiotic with placebo for acute cough in adults. BMJ. 1998;316(7135):906-10. [pmid: 9552842]. [pmcid: 28496].
35 Fowlie PW. Prophylactic indomethacin: systematic review and meta-analysis. Arch Dis Child Fetal Neonatal Ed. 1996;74(2):F81-7. [pmid: 8777672].
36 Freemantle N, Cleland J, Young P, Mason J, Harrison J. beta Blockade after myocardial infarction: systematic review and meta regression analysis. BMJ. 1999;318(7200):1730-7. [pmid: 10381708]. [pmcid: 31101].
37 Gadsby JG, Flowerdew MW. The effectiveness of transcutaneous electrical nerve stimulation (TENS) and acupuncture-like transcutaneous electrical nerve stimulation (ALTENS) in the treatment of patients with chronic low back pain. Cochrane Database Syst Rev. 1996.
38 Gotzsche PC, Gjorup I, Bonnen H, Brahe NE, Becker U, Burcharth F. Somatostatin v placebo in bleeding oesophageal varices: randomised trial and meta-analysis. BMJ. 1995;310(6993):1495-8. [pmid: 7787594]. [pmcid: 2549875].
39 Goulenok C, Bernard B, Cadranel JF, et al. Flumazenil vs. placebo in hepatic encephalopathy in patients with cirrhosis: a meta-analysis. Aliment Pharmacol Ther. 2002;16(3):361-72. [pmid: 11876688].
40 Goulis J, Leandro G, Burroughs AK. Randomised controlled trials of ursodeoxycholic-acid therapy for primary biliary cirrhosis: a meta-analysis. Lancet. 1999;354(9184):1053-60. [pmid: 10509495].
41 Griffiths J, Barber VS, Morgan L, Young JD. Systematic review and meta-analysis of studies of the timing of tracheostomy in adult patients undergoing artificial ventilation. BMJ. 2005;330(7502):1243. [pmid: 15901643]. [pmcid: 558092].
42 Hart RG, Halperin JL, McBride R, Benavente O, Man-Son-Hing M, Kronmal RA. Aspirin for the primary prevention of stroke and other major vascular events: meta-analysis and hypotheses. Arch Neurol. 2000;57(3):326-32. [pmid: 10714657].
43 Hood SC, Moher D, Barber GG. Management of intermittent claudication with pentoxifylline: meta-analysis of randomized controlled trials. Cmaj. 1996;155(8):1053-9. [pmid: 8873633]. [pmcid: 1335354].
44 Hotopf M, Hardy R, Lewis G. Discontinuation rates of SSRIs and tricyclic antidepressants: a meta-analysis and investigation of heterogeneity. Br J Psychiatry. 1997;170:120-7. [pmid: 9093499].
45 Ioannidis JP, Cappelleri JC, Lau J, et al. Early or deferred zidovudine therapy in HIV-infected patients without an AIDS-defining illness. Ann Intern Med. 1995;122(11):856-66. [pmid: 7741372].
46 Chen W, Gluud C. Vaccines for preventing hepatitis B in health-care workers. Cochrane Database Syst Rev. 2005(4):CD000100.
47 Jefferson T, Deeks JJ, Demicheli V, Rivetti D, Rudin M. Amantadine and rimantadine for preventing and treating influenza A in adults. Cochrane Database Syst Rev. 2004(3):CD001169.
48 Jong P, Demers C, McKelvie RS, Liu PP. Angiotensin receptor blockers in heart failure: meta-analysis of randomized controlled trials. J Am Coll Cardiol. 2002;39(3):463-70. [pmid: 11823085].
49 Keenan SP, Kernerman PD, Cook DJ, Martin CM, McCormack D, Sibbald WJ. Effect of noninvasive positive pressure ventilation on mortality in patients admitted with acute respiratory failure: a meta-analysis. Crit Care Med. 1997;25(10):1685-92. [pmid: 9377883].
50 Koch A, Bouges S, Ziegler S, Dinkel H, Daures JP, Victor N. Low molecular weight heparin and unfractionated heparin in thrombosis prophylaxis after major surgical intervention: update of previous meta-analyses. Br J Surg. 1997;84(6):750-9. [pmid: 9189079].
51 Laine L, Schoenfeld P, Fennerty MB. Therapy for Helicobacter pylori in patients with nonulcer dyspepsia. A meta-analysis of randomized, controlled trials. Ann Intern Med. 2001;134(5):361-9. [pmid: 11242496].
52 Lensing AW, Prins MH, Davidson BL, Hirsh J. Treatment of deep venous thrombosis with low-molecular-weight heparins. A meta-analysis. Arch Intern Med. 1995;155(6):601-7. [pmid: 7887755].
53 Letelier LM, Udol K, Ena J, Weaver B, Guyatt GH. Effectiveness of amiodarone for conversion of atrial fibrillation to sinus rhythm: a meta-analysis. Arch Intern Med. 2003;163(7):777-85. [pmid: 12695268].
54 McIntyre PB, Berkey CS, King SM, et al. Dexamethasone as adjunctive therapy in bacterial meningitis. A meta-analysis of randomized clinical trials since 1988. JAMA. 1997;278(11):925-31. [pmid: 9302246].
55 Michels KB, Yusuf S. Does PTCA in acute myocardial infarction affect mortality and reinfarction rates? A quantitative overview (meta-analysis) of the randomized clinical trials. Circulation. 1995;91(2):476-85. [pmid: 7805253].

#### Quantitative signal involving primary outcome but no qualitative signal

56 Anand SS, Yusuf S. Oral anticoagulant therapy in patients with coronary artery disease: a meta-analysis. JAMA. 1999;282(21):2058-67. [pmid: 10591389].
57 Dalby M, Bouzamondo A, Lechat P, Montalescot G. Transfer for primary angioplasty versus immediate thrombolysis in acute myocardial infarction: a meta-analysis. Circulation. 2003;108(15):1809-14. [pmid: 14530206].
58 Kong DF, Califf RM, Miller DP, et al. Clinical outcomes of therapeutic agents that block the platelet glycoprotein IIb/IIIa integrin in ischemic heart disease. Circulation. 1998;98(25):2829-35. [pmid: 9860783].

#### Any signal

Quantitative signal involving non-primary outcome or any of three pre-defined criteria for changes in the amount or precision of information: increase in total number of trials by ≥ 50%, increase in total number of participants by ≥ 50%, publication of a new trial with sample size ≥ 3 times size of previous largest trial, relative of change ≥ 50% for the width of the 95% confidence interval.

59 Adams NP, Bestall JB, Malouf R, Lasserson TJ, Jones PW Inhaled beclomethasone versus placebo for chronic asthma. Cochrane Database Syst Rev. 2005(1):CD002738.
60 Arroll B, Kenealy T. Antibiotics for the common cold and acute purulent rhinitis. Cochrane Database Syst Rev. 2005(3):CD000247.
61 Barza M, Ioannidis JP, Cappelleri JC, Lau J. Single or multiple daily doses of aminoglycosides: a meta-analysis. BMJ. 1996;312(7027):338-15. [pmid: 8611830]. [pmcid: 2350289].
62 Beale RJ, Bryg DJ, Bihari DJ. Immunonutrition in the critically ill: a systematic review of clinical outcome. Crit Care Med. 1999;27(12):2799-805. [pmid: 10628629].
63 Brocklebank D, Wright J, Cates C. Systematic review of clinical effectiveness of pressurised metered dose inhalers versus other hand held inhaler devices for delivering corticosteroids in asthma. BMJ. 2001;323(7318):896-900. [pmid: 11668133]. [pmcid: 58536].
64 Chronicle E, Mulleners W. Anticonvulsant drugs for migraine prophylaxis. Cochrane Database Syst Rev. 2004(3):CD003226.
65 de Ferranti SD, Ioannidis JP, Lau J, Anninger WV, Barza M. Are amoxycillin and folate inhibitors as effective as other antibiotics for acute sinusitis? A meta-analysis. BMJ. 1998;317(7159):632-7. [pmid: 9727991]. [pmcid: 28657].
66 Del Mar CB, Glasziou PP, Spinks AB. Antibiotics for sore throat. Cochrane Database Syst Rev. 2004(2):CD000023.
67 Del Mar C, Glasziou P, Hayem M. Are antibiotics indicated as initial treatment for children with acute otitis media? A meta-analysis. BMJ. 1997;314(7093):1526-9. [pmid: 9183201]. [pmcid: 2126788].
68 Demicheli V, Rivetti D, Deeks JJ, Jefferson TO. Vaccines for preventing influenza in healthy adults. Cochrane Database Syst Rev. 2004(3):CD001269.
69 Ducharme F, Schwartz Z, Hicks G, Kakuma R. Addition of anti-leukotriene agents to inhaled corticosteroids for chronic asthma. Cochrane Database Syst Rev. 2004(2):CD003133.
70 Eikelboom JW, Anand SS, Malmberg K, Weitz JI, Ginsberg JS, Yusuf S. Unfractionated heparin and low-molecular-weight heparin in acute coronary syndrome without ST elevation: a meta-analysis. Lancet. 2000;355(9219):1936-42. [pmid: 10859038].
71 Wahlbeck K, Cheine M, Essali MA. Clozapine versus typical neuroleptic medication for schizophrenia. Cochrane Database Syst Rev. 2000(2):CD000059.
72 French RS, Cowan FM, Mansour D, et al. Levonorgestrel-releasing (20 microgram/day) intrauterine systems (Mirena) compared with other methods of reversible contraceptives. Bjog. 2000;107(10):1218-25. [pmid: 11028571].
73 Gisbert JP, Pajares JM. Systematic review and meta-analysis: is 1-week proton pump inhibitor-based triple therapy sufficient to heal peptic ulcer?. Aliment Pharmacol Ther. 2005;21(7):795-804. [pmid: 15801914].
74 Jull AB, Waters J, Arroll B. Pentoxifylline for treating venous leg ulcers. Cochrane Database Syst Rev. 2002(1):CD001733.
75 Kellum JA, J MD. Use of dopamine in acute renal failure: a meta-analysis. Crit Care Med. 2001;29(8):1526-31. [pmid: 11505120].
76 Laine L, Cook D. Endoscopic ligation compared with sclerotherapy for treatment of esophageal variceal bleeding. A meta-analysis. Ann Intern Med. 1995;123(4):280-7. [pmid: 7611595].
77 Lengeler C. Insecticide-treated bed nets and curtains for preventing malaria. Cochrane Database Syst Rev. 2004(2):CD000363.
78 Macones GA, Berlin M, Berlin JA. Efficacy of oral beta-agonist maintenance therapy in preterm labor: a meta-analysis. Obstet Gynecol. 1995;85(2):313-7. [pmid: 7824252].

#### New trials but no signal

79 Bacaltchuk J, Hay P. Antidepressants versus placebo for people with bulimia nervosa. Cochrane Database Syst Rev. 2003(4):CD003391.
80 Bell-Syer SE, Hart R, Crawford F, Torgerson DJ, Tyrrell W, Russell I. Oral treatments for fungal infections of the skin of the foot. Cochrane Database Syst Rev. 2002(2):CD003584.
81 Bjelakovic G, Nikolova D, Simonetti RG, Gluud C. Antioxidant supplements for prevention of gastrointestinal cancers: a systematic review and meta-analysis. Lancet. 2004;364(9441):1219-28. [pmid: 15464182].
82 Borgaonkar MR, MacIntosh DG, Fardy JM. A meta-analysis of antimycobacterial therapy for Crohn's disease. Am J Gastroenterol. 2000;95(3):725-9. [pmid: 10710065].
83 Crowley PA. Antenatal corticosteroid therapy: a meta-analysis of the randomized trials, 1972 to 1994. Am J Obstet Gynecol. 1995;173(1):322-35. [pmid: 7631713].
84 Cullum N, Nelson EA, Fletcher AW, Sheldon TA. Compression for venous leg ulcers. Cochrane Database Syst Rev. 2001(2):CD000265.
85 Eikelboom JW, Quinlan DJ, Douketis JD. Extended-duration prophylaxis against venous thromboembolism after total hip or knee replacement: a meta-analysis of the randomised trials. Lancet. 2001;358(9275):9-15. [pmid: 11454370].
86 Feigin VL, Rinkel GJ, Algra A, Vermeulen M, van Gijn J. Calcium antagonists in patients with aneurysmal subarachnoid hemorrhage: a systematic review. Neurology. 1998;50(4):876-83. [pmid: 9566366].
87 Fink HA, Mac Donald R, Rutks IR, Nelson DB, Wilt TJ. Sildenafil for male erectile dysfunction: a systematic review and meta-analysis. Arch Intern Med. 2002;162(12):1349-60. [pmid: 12076233].
88 Garg R, Yusuf S. Overview of randomized trials of angiotensin-converting enzyme inhibitors on mortality and morbidity in patients with heart failure. Collaborative Group on ACE Inhibitor Trials. JAMA. 1995;273(18):1450-6. [pmid: 7654275].
89 Heidenreich PA, McDonald KM, Hastie T, et al. Meta-analysis of trials comparing beta-blockers, calcium antagonists, and nitrates for stable angina. JAMA. 1999;281(20):1927-36. [pmid: 10349897].
90 Hodson EM, Knight JF, Willis NS, Craig JC. Corticosteroid therapy in nephrotic syndrome: a meta-analysis of randomised controlled trials. Arch Dis Child. 2000;83(1):45-51. [pmid: 10868999]. [pmcid: 1718389].
91 Holdgate A, Pollock T. Systematic review of the relative efficacy of non-steroidal anti-inflammatory drugs and opioids in the treatment of acute renal colic. BMJ. 2004;328(7453):1401. [pmid: 15178585]. [pmcid: 421776].
92 Jackson JL, O'Malley PG, Tomkins G, Balden E, Santoro J, Kroenke K. Treatment of functional gastrointestinal disorders with antidepressant medications: a meta-analysis. Am J Med. 2000;108(1):65-72. [pmid: 11059442].

#### No new trials

93 Barr RG, Bourbeau J, Camargo CA, Ram FS. Inhaled tiotropium for stable chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2005(2):CD002876.
94 Edmonds ML, Camargo CA, Brenner BE, Rowe BH. Inhaled steroids in acute asthma following emergency department discharge (Cochrane Review). In: The Cochrane Library, Issue 1, 2001. Oxford: Update Software. 2001.
95 Colman I, Brown MD, Innes GD, Grafstein E, Roberts TE, Rowe BH. Parenteral metoclopramide for acute migraine: meta-analysis of randomised controlled trials. BMJ. 2004;329(7479):1369-73. [pmid: 15550401]. [pmcid: 535449].
96 Furukawa TA, McGuire H, Barbui C. Meta-analysis of effects and side effects of low dosage tricyclic antidepressants in depression: systematic review. BMJ. 2002;325(7371):991. [pmid: 12411354]. [pmcid: 131022].
97 Gourlay SG, Stead LF, Benowitz NL. Clonidine for smoking cessation. Cochrane Database Syst Rev. 2004(3):CD000058.
98 Hart RG, Benavente O, McBride R, Pearce LA. Antithrombotic therapy to prevent stroke in patients with atrial fibrillation: a meta-analysis. Ann Intern Med. 1999;131(7):492-501. [pmid: 10507957].
99 Iorio A, Agnelli G. Low-molecular-weight and unfractionated heparin for prevention of venous thromboembolism in neurosurgery: a meta-analysis. Arch Intern Med. 2000;160(15):2327-32. [pmid: 10927730].
100 Ko DT, Hebert PR, Coffey CS, Sedrakyan A, Curtis JP, Krumholz HM. Beta-blocker therapy and symptoms of depression, fatigue, and sexual dysfunction. JAMA. 2002;288(3):351-7. [pmid: 12117400].

## References

1 Moher D, Tetzlaff J, Tricco AC, et al. Epidemiology and reporting characteristics of systematic reviews. PLoS Med. 2007;4(3):e78. [pmid: 17388659].
2 Shojania KG, Bero LA. Taking advantage of the explosion of systematic reviews: an efficient MEDLINE search strategy. Eff Clin Pract. 2001;4(4):157-162. [pmid: 11525102].
3 Moher D, Tsertsvadze A. Systematic reviews: when is an update an update?. Lancet. 2006;367(9514):881-883. [pmid: 16546523].
4 Moher D, Tsertsvadze A, Tricco A et al. When and how to update systematic reviews: a methodological systematic review. Journal of Clinical Epidemiology (in press) 2007;
5 Barrowman NJ, Fang M, Sampson M, et al. Identifying null meta-analyses that are ripe for updating. BMC Med Res Methodol. 2003;3(1):13. [pmid: 12877755]. [pmcid: 212708].
6 Sutton AJ, Cooper NJ, Jones DR et al. Evidence-based sample size calculations based upon updated meta-analysis. Stat Med 2006;
7 Shekelle PG, Ortiz E, Rhodes S, et al. Validity of the Agency for Healthcare Research and Quality clinical practice guidelines: how quickly do guidelines become outdated?. JAMA. 2001;286(12):1461-1467. [pmid: 11572738].
8 Higgins, J. P. T. and Green, S.Cochrane Handbook for Systematic Reviews of Interventions 4.2.5. Higgins, J. P. T. and Green, S. Available at: http://www.cochrane.org/resources/handbook/hbook.htm Chichester, UK: John Wiley & Sons, Ltd. 2005.
9 The Cochrane Collaboration. Maintaining your review. The Cochrane Collaboration open learning material Module 19 2002; available at: http://www.cochrane-net.org/openlearning/HTML/mod19.htm
10 Chalmers I, Enkin M, Keirse MJ. Preparing and updating systematic reviews of randomized controlled trials of health care. Milbank Quarterly. 1993;71(3):411-437. [pmid: 8413069].
11 Purpose and Procedure. ACP Journal Club. Available at: http://www.acpjc.org/shared/purpose_and_procedure.htm 2007. Accessed: 2-7-2007.
12 Toma M, McAlister FA, Bialy L, et al. Transition from meeting abstract to full-length journal article for randomized controlled trials. JAMA. 2006;295(11):1281-1287. [pmid: 16537738].
13 Ioannidis JP. Contradicted and initially stronger effects in highly cited clinical research. JAMA. 2005;294(2):218-228. [pmid: 16014596].
14 Ioannidis JP, Haidich AB, Pappa M, et al. Comparison of evidence of treatment effects in randomized and nonrandomized studies. JAMA. 2001;286(7):821-830. [pmid: 11497536].
15 Survey Monkey. Available at: http://www.surveymonkey.com/ 2006. Accessed: 4-20-2006.
16 Eysenbach G, Wyatt J. Using the Internet for surveys and health research. J Med Internet Res. 2002;4(2):e13. [pmid: 12554560].
17 Wyatt JC. When to use web-based surveys. J Am Med Inform Assoc. 2000;7(4):426-429. [pmid: 10887170]. [pmcid: 61446].
18 Dillman DA. Internet and interactive voice response surveys. In: Mail and Internet Surveys: The Tailored Design Method. New York, NY.: John Wiley & Sons Incorporated, 2000.
19 Edwards P, Roberts I, Clarke M, et al. Increasing response rates to postal questionnaires: systematic review. BMJ. 2002;324(7347):1183. [pmid: 12016181]. [pmcid: 111107].
20 Leece P, Bhandari M, Sprague S, et al. Internet versus mailed questionnaires: a controlled comparison (2). J Med Internet Res. 2004;6(4):e39. [pmid: 15631963].
21 Crumley ET, Wiebe N, Cramer K, et al. Which resources should be used to identify RCT/CCTs for systematic reviews: a systematic review. BMC Med Res Methodol. 2005;5:24. [pmid: 16092960]. [pmcid: 1232852].
22 Ware JH. The limitations of risk factors as prognostic tools. N Engl J Med. 2006;355(25):2615-2617. [pmid: 17182986].
23 Many reviews are systematic but some have better systems than others [Editorial]. PLoS Med 2007; 4(3)
24 Carter AO, Griffin GH, Carter TP. A survey identified publication bias in the secondary literature. J Clin Epidemiol. 2006;59(3):241-245. [pmid: 16488354].
25 Cappelleri JC, Ioannidis JP, Schmid CH, et al. Large trials vs meta-analysis of smaller trials: how do their results compare?. JAMA. 1996;276(16):1332-1338. [pmid: 8861993].
26 LeLorier J, Gregoire G, Benhaddad A, et al. Discrepancies between meta-analyses and subsequent large randomized, controlled trials. N Engl J Med. 1997;337(8):536-542. [pmid: 9262498].
27 Benson K, Hartz AJ. A comparison of observational studies and randomized, controlled trials. N Engl J Med. 2000;342(25):1878-1886. [pmid: 10861324].
28 Concato J, Shah N, Horwitz RI. Randomized, controlled trials, observational studies, and the hierarchy of research designs. N Engl J Med. 2000;342(25):1887-1892. [pmid: 10861325]. [pmcid: 1557642].
29 Pogue JM, Yusuf S. Cumulating evidence from randomized trials: utilizing sequential monitoring boundaries for cumulative meta-analysis. Control Clin Trials. 1997;18(6):580-593. [pmid: 9408720].
30 Shekelle P, Eccles MP, Grimshaw JM, et al. When should clinical guidelines be updated?. BMJ. 2001;323(7305):155-157. [pmid: 11463690]. [pmcid: 1120790].