# Acknowledgments

We would like to acknowledge the guidance and expertise contributed to this project by the Technical Expert Panel members:

- David Atkins - Chief Medical Officer, Agency for Healthcare Research and Quality
- Paul Shekelle - RAND (USA)
- Evelyn P. Whitlock - Kaiser Permanente Center for Health Research (USA)
- Cynthia Mulrow - University of Texas, San Antonio and Annals of Internal Medicine (USA)
- Doug Altman - Center for Statistics in Medicine (UK)
- Martin Eccles - Center for Health Services Research, Newcastle University (UK)
- P.J. Devereaux - McMaster University Health Sciences Centre (CAN)

We would like to acknowledge the contributions of members of the University of Ottawa Evidence-based Practice Center and others. Many of these researchers made significant contributions to portions of the project.

- Lorri Puil, Director of Systematic Reviews, Chalmers Research Group, for support and supervision of research staff
- Keith O'Rourke and Nicholas J Barrowman, for statistical advice
- Andrea Tricco for guidance with survey methods
- Alexander Tsertsvadze, for early methodological discussions and assistance with screening
- Tanya Armour, for mentorship of team members
- Jessie McGowan, for guidance with search method development
- Raymond Daniel, for search assistance and document acquisition
- Alla E. Iansavichene, for search assistance and data quality management
- Mary Ocampo, for technical and administrative assistance
- Alison Jenkins, for development of the meta-analytic Excel worksheet