# Discussion

Among 100 systematic reviews, qualitative or quantitative signals for updating occurred for 57% (95% CI: 47%– 67%) of the cohort. Median survival free of a signal for updating was 5.5 years (95% CI: 4.6–7.6). However, in 23 cases, a signal for updating occurred within 2 years, in 15 cases the signal occurred in less than 1 year, and, for 7 reviews, signals for updating had already occurred at the time of publication. Cardiovascular medicine, heterogeneity in the original review, and publication of a new trial larger than the previous largest trial were associated with shorter survival times, while inclusion of greater than 13 studies in the original review was associated with increased survival. However, no feature of the original review significantly predicted a signal for updating occurring within 2 years of publication. Using a search protocol combining PubMed Related Articles and a subject search limited with the optimized clinical query search filter for therapies identified almost all new signaling evidence with median screening burden of 71 new records per review.

Signals for updating occurred frequently and within relatively short timelines. While certain features were associated with shorter survival, prediction of the need to update a particular systematic review within specific time frames of interest (e.g., 2 years, as in the main analysis, or 1 or 3 years as checked in sensitivity analyses) does not appear feasible. It is worth emphasizing that this result is unlikely to change with further research. We tested all readily discernible features of systematic reviews with plausible relationships to the need for updating. We found several factors with statistically significant associations with shorter survival, including two with hazard ratios in the range of 2–3, magnitudes that would certainly be of interest epidemiologically. However, as recently highlighted in a discussion of prognostic tools, ^22^ associations of this magnitude, despite being of epidemiological interest, generally do not give rise to useful prediction tools. The strength of association required for an epidemiological feature by itself to provide a screening test with useful sensitivity and specificity is orders of magnitude higher (i.e., the factor would need to confer a risk of approximately 200–300 fold). It is extremely unlikely that any features of the original systematic review—alone or in combination—would ever increase the risk of a signal for updating within 2 years to such an extent that these factors could usefully identify reviews in need of greater vigilance (i.e., with acceptable positive and negative predictive values). As such, surveillance of the literature for new evidence holds greater promise than relying on features of the original review to identify reviews likely to need updating within short time periods. A preliminary approach is proposed here (below), but may be refined through additional research.

We also evaluated the extent to which growth in the literature varied across broad areas of inquiry, as defined by clinical specialty (e.g., cardiovascular medicine, infectious diseases, obstetrics and gynecology, psychiatry), in order to determine if different clinical areas warranted greater attention with respect to updating. At this broad level, we found that, while the absolute number of new trials published each year does vary quite widely (from a low of 61 new RCTs per year in critical care medicine to a high of 1238 RCTs per year in peripheral vascular diseases), the doubling time for RCTs was surprisingly constant across fields. Linear growth results in ever-longer doubling times for an evidence base, which may bring stability to reviews where shifts in the direction of research are not a complicating factor, i.e., for reviews that could be updated through cumulative meta-analysis.

This combination of wide variation in absolute numbers of trials but minimal variation in rate of growth suggests that clinical fields probably vary in the number of reviews at risk for requiring an update, but that the risk per review does not differ dramatically as a function of clinical field. Importantly, this analysis of clinical fields involved only the rate of production of new evidence at a very broad level. In the cohort analysis, we did find that the specific field of cardiovascular medicine conferred shorter survival time. This finding may reflect features of the field other than the rate of growth, as the rate of 814 new RCTs per year for cardiovascular medicine fell approximately in the middle of the range of values seen across all 13 clinical areas. Number of publications is but one indicator of the amount of new information available. Its appeal it that it is easily counted. Number of new trials, number of patients (new participant ratio), and number of new events are other potentially relevant units of information for determining the need to update. Although the rate of new trial accrual in cardiovascular disease was ranked six among the clinical areas examined, the studies were large compared to other areas (Figure 2).

Alternatively, the similar rates of growth of the literature at the level of broad clinical areas may mask wide variations in growth rates for specific topics within a field. For instance, the rate of new trials per year in cardiology includes the rate for new RCTs in valvular heart disease, which is very small, as well as the rate for new RCTs related to acute coronary syndromes, which is quite high. In fact, in any of the broad clinical fields, there are likely specific topics that have much greater research activity than the average indicated by the broad field as a whole. Systematic reviews of such rapidly changing topics are likely to be challenging and resource-intensive to maintain.

## Practical Implications

Many journals, including those with high impact factors, now routinely publish systematic reviews. However, publishing updates of systematic reviews presents challenges because journals, still largely print in format, only have a certain amount of space to provide for reporting systematic reviews. It is unclear whether they will devote any space for publishing updates. Although this situation might be less problematic for electronic journals, at least one of which is committed to publishing systematic review updates, ^23^ journal ‘real estate’ available for updating is largely unknown. Print journals might consider publishing updates as “web-only” material. While this would avoid the problem of limited journal ‘real estate,’ it would still add to the peer review and editing workload for journals. In the case of AHRQ, the EPC program might want to consider developing its own peer reviewed, open access, indexed journal. Such a move might open an important dissemination venue for publishing systematic review updates.

Since its inauguration in 1997 the EPC program has already produced more than 150 evidence reports. And unlike other systematic reviews, which typically focus on a single question, EPC reports usually contain multiple systematic reviews within a single evidence report. Thus, EPC reports may require updating to an even greater extent than indicated by the present analysis, given the multiple topics addressed in each EPC report. With the development of the Medicare Modernization Act and the subsequent development of the clinical effectiveness reviews, and the renewal of the EPC program for another five years, there is likely to be a growing number of completed evidence reports. As with other systematic reviews, the utility of these evidence reports depends on their remaining up to date. Yet, most reviews are not kept up to date. ^1^ While it may be possible to commission each EPC with responsibility for keeping their completed evidence reports up to date, there are obvious drawbacks to such an approach. For example, principal authors of some reviews will not remain at the same centers, making updating more complicated. Competing demands on authors' time as well as insufficient resources allocated to updating represent additional barriers.

Alternatively, the EPC program might commission one of its existing EPCs to centralize and harmonize the updating functions for the entire EPC program. Such an approach would likely be cost efficient and relieve pressures on individual EPCs to focus on identifying new evidence. Moreover, centralizing the updating process, an approach the Cochrane Collaboration is currently experimenting with, would facilitate efforts to study and improve the process of updating. This opportunity is important as the current evidence base to inform how and when to update systematic reviews is limited and new approaches and methodologies need to be developed. Through internal EPC knowledge translation activities such developments could be shared with other EPCs and the wider research and health policy community.

### For Users of Systematic Reviews

Users of systematic reviews need to recognize that reviews can become out of date within relatively short time frames. Due to the peer review process, including sequential rejections at different journals in the case of most reviews not published in high impact journals, considerable time may elapse between the date of the last electronic search and the time of publication. Although our sample had an average ‘lag’ period (between the reported last search and eventual publication date) of a little more than 1 year, this average result reflects considerable variation. In fact, over 50% of the cohort had a publication lag of 1.4 years or greater and 25% had a lag of 2.1 years or greater.

To assess the degree to which a given systematic review remains up to date, readers should examine the most recent search date reported. If the search is over two years old, or if readers cannot ascertain this information from the report, then readers should seriously consider the possibility that the review is out of date. In such cases, readers might consider searching for a new systematic review or new primary studies that address the topic of interest. Another option consists of using secondary publication sources, such as the ACP Journal Club or Clinical Evidence, to identify recently published reviews or primary studies.

### For Producers of Systematic Reviews

The finding that 7% of systematic reviews had signals for updating at the time of publication suggests that authors and publishers need to manage production and dissemination times more efficiently. Our data, drawn from a broad range of systematic reviews, including paper-based journal articles, Cochrane reviews, and health technology assessments, revealed that the median time from last search date to publication was 1.4 years, with a 25^th^ percentile of 0.9 years. However, among reviews that explicitly indicated that an update to the search was performed, the 25^th^ percentile was 28 weeks (0.5 years). Achievement of this benchmark across a greater proportion of systematic reviews would produce important increases in survival time.

It is unclear to what extent publishers of systematic reviews can expedite the peer review and publication process for systematic reviews any more than already attempted for submissions of all types. However, authors can control two of the factors that contribute to publication lags. First, they can update searches prior to submission to capture any evidence that may have emerged during preparation of the review. Second, authors might consider submitting their work to the journals most likely to accept a given review in order to avoid delays due to multiple iterations of the peer review process. When the process of submission and rejection from other journals has resulted in the passage of 1 year or more since the date of the last search, authors should consider updating the search prior to resubmission.

### Proposed Surveillance Search Methodology

Searches constructed to conduct systematic reviews typically have low precision (often less than 5%) because they maximize recall in order to avoid missing any relevant evidence. Signal detection against the noise of very low precision makes standard systematic review searches inefficient for the purpose of identifying the need for updating. Good recall of the most influential new evidence would ideally be balanced with a low screening burden. Among the search strategies tested, the combination of two, Related Articles and the optimized Clinical Query, was sufficient to detect all relevant new studies indexed by the date of the updating signal in all but 4 cases. They achieved this recall with precision of approximately 35%. Assessing the performance of our methodology required that we screen candidates sequentially by indexing date in order to identify the earliest point at which a signal could be detected. Using this approach, we found that we needed to screen an average of 71 records per review to detect a signal for updating. In practice, however, there would be no requirement to screen purely in chronological order. For instance, one might first review citations retrieved from the top 5 general journals and the highest impact specialty journals related to the topic of interest. Triaging by journal source would likely reduce the ‘number needed to screen’ substantially.

In this retrospective assessment, reviewing newer systematic reviews was a useful adjunct to identifying new trials. This technique would have less utility for real time surveillance as lag of at least a year can be expected between trial publication and publication of a systematic review including that trial. Also, relying on newer systematic reviews means that the horse will already be out of the barn, as one would in effect be detecting the need for updating by identifying that an update had in fact been performed. Nonetheless, including both systematic reviews and RCTs adds little work, as the number of newer systematic reviews that require consideration will generally be small.

### Review Method

Our approach consisted of applying explicit quantitative and qualitative criteria to new evidence. To ascertain quantitative criteria, we selected a limited number of major outcomes of interest and updated the meta-analytic estimates using fixed effects models. To ascertain qualitative criteria, we monitored for new evidence that changed the certainty of the previous findings, identified new harms or major caveats to the previous findings, among other clinically relevant changes in evidence. We did not compare this method to other possible approaches, but the approach has substantial face validity, and it proved feasible across the cohort of 100 systematic reviews.

As a starting point, we propose that major outcomes be identified for monitoring. The outcomes selected would be sufficiently central to the purpose of the review that signals for changed evidence would warrant undertaking an update. Surveillance searching in the form of the related article protocol and clinical queries would than be initiated, with a search frequency of twice yearly. Search results would than be screened and the robustness of findings from the original review be assessed in the face of the new evidence.

The method could be refined or tailored to different circumstances, including changing the way in which it is operationalized. Certainly the original team of authors for a given systematic review could carry out the same methodology. Alternatively, an agency that supports systematic reviews could carry out some of the surveillance and screening with a team of reviewers, but would need to involve one or more authors from the original review or others with expertise in the relevant content area.

### Review Frequency

Agencies that fund systematic reviews should consider how often it is practical to conduct searches, particularly electronic searches, to identify potential new evidence for inclusion in a systematic review. We found that 4% of reviews had a signal for updating within 1 year of the last search date, and that 11% of reviews had signals for updating within 2 years of the last search date. Assuming that 4% is an acceptable risk and that 11% approaches an unacceptable risk, we suggest performance of the electronic searching process approximately once every six months. This frequency would allow sufficient time that, in the event new evidence is identified, reviewers would be able to carry out an update to their existing review along with publication within another 12 to 18 months, bringing the entire process to 2 years or less.

### Central or Distributed Surveillance and Updating

For agencies or organizations that sponsor systematic reviews, the functions of surveillance, the decision to update, and actually performing the update could be central or distributed. A central approach would have an editorial group, a specialized team or administrative authority undertake these activities. A distributed approach would have these activities performed by the team that prepared the systematic review. Central surveillance is feasible, and a central approach may be better able to integrate factors other than new evidence, that may influence the decision to update. Central surveillance permits a standard methodology that may facilitate priority setting when many reviews have signals for update.

Some updating functions, such as determination that a review is not in need of update, can be done centrally. When a major update is needed, it would most efficiently be performed by the authors of the original review.

Review authors could develop and submit an updating brief as part of the initial review - included and excluded files, explicit identification of the 3 newest and 3 largest included trials, and a summary of any information known to them at the time of submission that is pertinent to updating, such as trial registration numbers for ongoing trials.

### Format of Update

Our results suggest that the risk factors we identified were not helpful in predicting signals for updating systematic reviews. Surveillance may prove to be more helpful although, as yet, it is unclear which of the several competing surveillance approaches might be most effective. Regardless of which method(s) will turn out to be most effective it is important to remember that these are only signals for updating. Deciding to ‘act upon’ an updating signal is likely to vary depending on several factors, such as priority setting by the funders or the interest in the topic. One approach to consider is to develop a decision tree model for each funder and/or producer. The details of such an approach are beyond the scope of the current project.

The flexibility and speed of amending electronic products, and the ability to retract obsolete versions makes that format attractive. Costs for both producers and users of electronic products are less than paper copies. Updating efforts should be restricted to the electronic version. Paper versions may be useful for initial dissemination to an important target audiences, however readers could be informed that only the electronic version is updated and so it should be considered the authoritative version.

### Surveillance Costs

Life cycle costing of information products, including systematic review, would include updating and retirement costs as well as the initial costs of production and dissemination. In factoring updating into life cycle planning, not only the cost but also the potential to leverage the initial investment by extending the useful life of the systematic review should be considered. We are unable to isolate costs of various aspects of our assessment from costs associated with the methodological research, such as enhanced record keeping and extended search methods. The time requirements described below are estimates.

One experienced searcher with a Masters in Library and Information Science and technical competencies in record manipulation was able to provide abstracts of new evidence for assessment in one working day per systematic review. Time for subsequent surveillance searches on the same systematic reviews would be considerably less. Additional time is needed for provision of full text of articles appearing relevant, which in this cohort was a median of 7 articles (inter-quartile range; 4–24).

The reviewers who assessed the new evidence for updating signals were trained in medicine and clinical epidemiology. Depending on the complexity of the review, the initial orientation to the review and set up for calculation of quantitative signals required one half to one day of effort. Time required to review candidate studies was dependent on the volume to be assessed. In this project, candidates spanned the period since the search of the original review and included the result sets of 5 search approaches that were under investigation. The median screening burden of the most effective combination of searches was 71 records per review (inter-quartile range 25 – 106) with a median of 7 obtained and assessed in full text format. Reviewing candidates and integrating relevant ones into the quantitative calculations required from one half to three days, but would be less in real-time surveillance. Validation with current expert opinion sources (which would not necessarily be available during real-time surveillance) and preparation of the case summary for review required several hours. Two to five systematic reviews could be considered in a two-hour team conference. Both preparation of the summary briefing and discussion at the team conference was more time consuming for reviews with signals than those without. With set up considered as a one-time cost, a review and summary might take 0.5 days for a review without a signal, and 1.5 days for one with a signal for updating.

### Survey

The survey data collected indicate that most organizations that fund and/or conduct systematic reviews research consider updating as important. Unfortunately, most do not have updating policies in place. However, establishing updating procedures is viewed as noteworthy and something organizations concur should be considered. There is strong agreement that the proposed definition of ‘update’ is a valid explanation of the process, which over time will help to establish common nomenclature for this emerging methodological area.

The majority of survey respondents support the idea of harmonization of updating efforts across groups. Coordinating updating resources across organizations may facilitate performance of regular searches to identify new literature, something that currently occurs inconsistently at best, and may also foster development and evaluation of formal methods to determine the need for updating. Also, of note, most respondents (84%) favored the development of a central registry, analogous to efforts within the clinical trials community, to coordinate updating activities across agencies and review groups.

Even though a high response rate was achieved, the sample denominator was small, as this was a pilot survey. Therefore, interpretation of results should be made with caution. While these survey data will help to establish a baseline of current updating practices and policies of agencies that sponsor systematic reviews, we plan to undertake a similar survey with a larger sample of organizations engaged in funding or producing systematic reviews.

## Limitations of the Review

We conducted the survival analysis using a retrospectively assembled cohort to determine how quickly systematic reviews require updating. The use of a retrospective cohort would be unlikely to bias the results of our analysis, but may have made the method appear more feasible than it would have appeared with a prospective cohort. The retrospective approach allowed us to use newer published systematic reviews, which aided in study identification for a substantial minority of cohort reviews. Relying exclusively on identification of new trials as they came out, as would occur with a prospective approach, would likely require greater effort. The retrospective approach also broadened the availability of published expert opinion to validate our conclusions. Instead of just editorials accompanying the new trials, we could use information from newer textbooks, practice guidelines, and systematic reviews to guide our assessments of the impact of new evidence on the findings of the original review.

We chose systematic reviews indexed in ACP Journal Club as our sampling frame in order to construct a cohort of reviews of above average quality that were also directly relevant to clinical practice. It is possible that choosing ACP Journal Club introduced a bias in our cohort, such as preferential inclusion of reviews with positive results. A recent comparison of randomized controlled trials summarized in ACP Journal Club with the general population of trials indexed in MEDLINE found that ACP Journal Club preferentially abstracts randomized controlled trials that report positive results. ^24^ ACP Journal Club might also preferentially focus on systematic reviews with positive results. While this could introduce some imbalance in the sample, such a bias would be unlikely to undermine our findings, as users of systematic reviews likely act on systematic reviews with positive findings more often than ones with null or negative findings. Nonetheless, understanding differences in updating between null reviews and those with clearly positive findings may represent a useful avenue for future methodological research.

We excluded from our analysis all qualitative reviews, reviews of non-therapeutic topics, individual patient data meta-analyses, and meta-regressions, based on our concerns that rates of change in evidence might differ across these different types of reviews. Restriction of our analysis to systematic reviews of randomized trials of conventional drugs, devices, or procedures that reported meta-analytic results for at least one dichotomous outcome may thus seem to have limited generalizability. However, as shown in Figure 2, excluding the records retrieved by our initial electronic search that were not systematic reviews, 139 (48%) of the first 287 systematic reviews were eligible for inclusion. (39 of the 139 eligible reviews were not included because they addressed topics that overlapped with earlier, eligible reviews, but they were nonetheless eligible for inclusion). Thus, while our cohort may appear highly selected, approximately half of the reviews indexed in ACP Journal Club were eligible for inclusion in our cohort, reflecting the fact that quantitative reviews of conventional drug therapies represent a substantial proportion of the systematic reviews directly relevant to clinical practice.

Our use of a structured approach for assessing differences between studies of the same topic without involving panels of experts represents the norm in methodological work of this type, including assessments of discrepancies between systematic reviews and large trials, ^25,^ ^26^ variations in results between studies of different designs, ^14,^ ^27,^ ^28^ differences in results presented in abstract form versus subsequent journal articles, ^12^ and highly cited trials versus other trials addressing the same question. ^13^ Nonetheless, assessments of the need to update previous systematic reviews would ideally include input by content experts who had evaluated the new evidence. As part of a follow-up project, we are conducting such an exercise with a subset of systematic reviews in this cohort to provide validation for the approach used. The idea of quantitative thresholds for indicating the need to update a previous analysis has face validity, but there is no basis for choosing a generic threshold. Therefore, we could have explored the impact on our results of different choices for these thresholds (e.g., using a threshold of 25% for changes in the magnitude of effect estimates, instead of 50%). Several alternatives were identified in a review of systematic review updating methods ^4^ including optimal information size ^29^ and new participant ratio. ^5^ Signals based on these quantities could be developed for real world updating in place of or in addition to these current criteria. In the case of an individual review, such approaches, especially optimal information size, would be attractive as they would be less arbitrary. However, operationalizing these methods over a cohort of some 100 reviews would require making a number of imputations that would themselves be somewhat arbitrary (e.g., generic values for event rates in control groups and expected effect sizes).

The idea of qualitative changes in evidence that warrant updating a previous review also has face validity, but, again, the specific signals we chose were somewhat arbitrary. However, the concepts captured by our qualitative signals (substantial changes in certainty, new harm, emergence of superior alternative treatments, important caveats about the patient populations who benefit from treatment, and other such issues) emerged from input from our technical advisory panel, as well a published framework for evaluating the need to update clinical practice guidelines. ^30^ Others might modify the specific criteria we chose, but we believe the qualitative criteria we used speak for themselves as representing clinically relevant changes in evidence.

Finally, this report presents several novel lines of enquiry concerning updating systematic reviews. We have stated what we believe to be logical implications of our findings, but it will be important to have others groups replicate of research and see whether such replication results in findings similar to ours. This is a rich area for research and as well as independently replicating, we strongly encourage others to extend and refine these lines of research.

## Conclusions

In a cohort of high quality systematic reviews directly relevant to clinical practice, signals for updating occurred frequently and within relatively short timelines. A number of features significantly affected survival, but none significantly predicted the need for updating within 2 years.

Methods for identifying reviews in need of updating based on surveillance for new evidence hold more promise. Several of the methods tested were feasible, yielding good recall of relevant new evidence with modest screening burdens.

The majority of organizations engaged in the funding or production of systematic reviews view the importance of updating systematic reviews as high to very high. Despite this recognition, most organizations report having no formal policy in place for updating previous systematic reviews. Slightly less than half of organizations performed periodic literature searches to identify new evidence, but searching frequencies varied widely, from monthly to every two years.

If systematic reviews are to achieve their stated goal of providing the best evidence to inform clinical decision making and healthcare policy, issues related to identifying reviews in need of updating will require much greater attention. In the meantime, publishers of systematic reviews should consider a policy of requiring authors to update searches performed over 12 months prior to submission. And, users of systematic reviews need to recognize that important new evidence can appear within short timelines. When considering the results of a particular systematic review, users should search for more recent reviews or trials to see if any exist and determine if the results are consistent with the previous review.