# Introduction

## Overview

Systematic reviews are being published with increasing frequency. One recent estimate is that 2500 new systematic reviews are published annually. ^1^ This high volume reflects the several key roles played by systematic reviews: synthesizing for clinicians the evidence addressing a given topic; providing the foundation for the development of clinical practice guidelines; and informing cost-effectiveness analyses and policy decisions. In addition, some granting agencies now require that researchers include systematic reviews in grant applications to support the rationale for proposed new research. Fulfilling these important roles requires that systematic reviews be up to date. However, almost no empiric data indicate the extent to which systematic reviews require updating or the intervals at which updates should be performed. Given the paucity of data on this important topic, and with funding through the Evidence-based Practice Center, we set out to generate data to help inform optimal approaches to updating.

## Background

The annual publication of systematic reviews has increased dramatically in recent years, ^2,^ ^2^ with an estimated 2500 new systematic reviews published per year. ^1^ The Cochrane Collaboration sets a goal of updating its reviews every 2 years, with the result that 38% of new Cochrane reviews represent updates of previous reviews (typically conducted by the same authors). ^1^ By contrast, only 2% of systematic reviews published in all other journals represent updates of previous reviews (whether conducted by the same authors or not). ^1^ Currently we have no way of knowing if either of these numbers adequately matches the true need for maintaining the currency of published systematic reviews.

Updating a previous systematic review requires resources. Even when the same authors update the review, carrying out the search and screening processes for potentially eligible new articles, abstracting new articles that are identified, and analyzing the results all take time. Agencies that commission and host systematic reviews thus face the challenge of how best to allocate resources between funding new reviews and supporting the maintenance of existing reviews. Even the process of determining if an aging review still represents a valid, even if no longer completely up to date, synthesis that can safely be left in the public domain, or new evidence alters the findings of the review to such an extent that withdrawing or archiving the review represents the preferred choice.

The goals of this effort are to determine the extent to which systematic reviews require updating and to ascertain approaches towards updating by organizations engaged in the funding or production of systematic reviews. This work builds upon and complements several pieces of work in which members of this team have participated over the past 24 months, including development of the first formal definition of updating to appear in the literature, ^3^ and a systematic review of existing methodologies for updating. ^4^ The evidence base proved to be quite limited, with a small body of literature on cumulative meta-analysis and the volume of new evidence needed to overturn previous meta-analytic results, ^5,^ ^6^ one evaluation of the shelf-life of 17 clinical practice guidelines produced for the Agency for Healthcare Research and Quality, ^7^ and some suggested approaches to updating from the Cochrane Collaboration. ^8^ – ^10^

Given this paucity of literature informing approaches to updating, we set out to evaluate how soon systematic reviews require updating, and how best to detect the need for updating through empirical study of a cohort of quantitative systematic reviews. We also sought to determine current practices with respect to updating through consultation with agencies involved with funding or producing systematic reviews.

## Key Questions Addressed in This Report

This evidence report aims to provide empiric data that address the following questions about updating systematic reviews.

1 How quickly do systematic reviews become out of date (i.e., what is the average ‘shelf life’ or ‘survival time’ of systematic reviews)?
2 Do any features of a given systematic review (including characteristics related to the content area, features of the included studies, and the nature of the results) increase or decrease ‘survival’ time?
3 What impact do publication time lags have on survival times for systematic reviews and what strategies can maximize the currency of systematic reviews at the time of publication?
4 Is the pattern of growth of evidence (e.g., the velocity of trial publication) within clinical areas predictive of the need to update?
5 Of agencies or organizations that fund or conduct systematic reviews, what are their existing policies or practices regarding updating systematic reviews?

Questions 1 to 4 are the main focus of this evidence report. They are addressed through identification and evaluation of new evidence pertaining to each of 100 systematic reviews, with an augmented sample of Cochrane reviews and AHRQ evidence reports for Question 3. Methods and main finding are described here in this extended overview. Each question is fully reported in a journal manuscript. The fifth question was addressed through a survey of 9 agencies as well as the EPCs, who also responded to several additional questions of particular interest to the AHRQ's EPC Program. The survey served as a pilot for a larger survey not conducted under the auspices of AHRQ. The material from the pilot will be reported in a separate manuscript. Methods and major results of the pilot survey are presented here; the larger survey will be reported in a subsequent manuscript.