# Survey Instrument

Wednesday, March 14, 2007

Updating Systematic Reviews Survey (University of Ottawa EPC)

Part I: Survey Information & Consent Form

Survey Title: Examining the Updating Practices of Healthcare Organizations that Fund and/or Conduct Systematic Review Research.

Background: To maintain their central role in informing clinical practice and health care policy, systematic reviews need to be up-to date. However, there is little available guidance about the appropriate timing or approach for updating of a particular evidence-base. Furthermore, updating policies and practices of organizations are often not explicit. There are general concerns about dated reviews; however, unlike other methodological areas, methods for updating systematic reviews remain understudied. Invitation to Participate: Your organization/group/unit has been chosen to participate in the first phase of this international survey on systematic review updating experiences given its involvement as a producer and/or funder of individual systematic reviews, or systematic reviews that are incorporated into clinical practice guidelines (CPGs) or health technology assessments (HTAs). Benefits: To better understand the updating experiences of those engaged in systematic reviews research, your responses would facilitate the advancement of best practice of updating methodology. This research is also of relevance to evidence-based agencies and researchers wishing to increase general performance and efficiency in their respective updating practices.

This research is funded by the U.S. Agency for Healthcare Research and Quality (AHRQ) Evidence-based Practice Center (EPC) Program and is being undertaken by the University of Ottawa Evidence-based Practice Center (UO-EPC) as part of an ongoing research program to examine a broad spectrum of issues pertaining to the methodology for updating systematic reviews. This will also be part of my MSc thesis in Public Health Sciences, University of Toronto, Canada. The Principle Investigator of this study is Dr. David Moher, Director of the UO-EPC and the Chalmers Research Group, based at the Children's Hospital of Eastern Ontario Research Institute (CHEO RI).

Instructions: As a participant, we are asking that you complete this survey, which is anticipated to take 30 minutes. Your organization's participation is voluntary and at any time you can leave the survey by clicking on “Exit this survey”. If you wish to return, your responses will be saved. You may withdraw from the study at any time and may refrain from answering any question by leaving it blank. All responses will remain strictly confidential and we anticipate minimal or no risk of harm from the research study. As a small token of our appreciation for completing this survey, you will be provided with a $10 gift certificate from Amazon.com. In order to obtain your consent, please review each statement below:

1 I am over 18 years of age and have the approval from my organization/group/unit to represent them as a participant of this survey;
2 I understand that the information obtained from the study will be used within a MSc thesis and that aggregate results from this survey may be published in peer-reviewed journals, however will not be directly identify organizations or groups by name in any reports or publications;
3 I understand that my organization's participation is voluntary and withdrawal from the study is allowed at any stage without adverse consequences for my organization;
4 I understand in representing my organization, that I may refrain from answering any questions should I so wish;
5 I understand that apart from the $10 Amazon gift card being offered for completing this survey, that I may not directly benefit from taking part in the study and that I will not receive any payment for participating in this research;
6 I understand that my organization will be provided with an executive summary of the results upon request;
7 I understand the Children's Hospital of Eastern Ontario and the University of Toronto's Research Ethics Boards have formally approved this survey;
8 I understand that data collected for this research will be retained for a period of 3 years, and will be stored in a secure location;
9 I understand that all responses will be kept strictly confidential;
10 I understand that I waive no legal rights by participating in this survey.

If you have any questions related to this survey, please contact:

Chantelle Garritty

University of Ottawa EPC Coordinator

CHEO RI, Ottawa, Canada

Email:cgarritty@cheo.on.ca

Tel: 613-737-7600 x 4117

Fax: 613-738-4800

If you have any questions or concerns about your rights as a research participant, please contact Sharon Haig (shaig@cheo.on.ca).

On behalf of the UO-EPC, thank you in advance for your time.

*I AGREE TO TAKE PART IN THIS STUDY (Confirming my consent to participate)

Yes _______ No ______

On behalf of the University of Ottawa EPC, thank you for your response.

If you still wish to exit this survey, please click on the Exit This Survey link provided above in the upper right corner of the screen.

Otherwise, click on ‘PREVIOUS’ to return to the preceding page to agree to take part in this survey.

Please review the following before starting the survey.

Systematic Review refers to a study that has a clear and comprehensive methodology. It includes explicit research questions, methods of searching the literature, criteria for including material, criteria for appraising quality and reliability of studies, and synthesis of research findings.

Please Note: For the purposes of this survey, the term Systematic Review is intended to be used broadly to reflect the following:

i) Conduct of individual or stand alone systematic reviews or
ii) Conduct of systematic reviews for use in Clinical Practice Guidelines (CPGs), or Health Technology Assessments (HTAs)

Therefore, please complete this survey based on the overall research synthesis work with which your organization/group/unit may be involved either as a producer, funder and/or both.

To view the survey instrument, please select the link below. This link will take you to a PDF version of the survey instrument.

Survey Instrument