# Growth of the Literature by Clinical Area

Cumulative publications by type and clinical area

X axis represents number of records, Y axis is year in each case.