# Searches by Clinical Area

Searches for each clinical area (a complete example, showing publication type and year limits is shown below.

Cardiac and cardiovascular systems; 1 exp Heart Diseases/; 2 Heart Failure, Congestive/; 3 or/1–2 | Obstetrics and Gynecology; 1 exp Genital Diseases, Female/; 2 exp Pregnancy Complications/; 3 or/1–2
Neurology; 1 exp Nervous System Diseases/ | Oncology; 1 exp Neoplasms/
Gastroenterology and Hepatology; 1 exp Gastrointestinal Diseases/ | Peripheral Vascular Diseases; 1 exp Vascular Diseases/
Critical Care Medicine; 1 exp Critical Care/; 2 exp Critical Illness/ | Psychiatry; 1 exp Mental Disorders/
Endocrinology and Metabolism; 1 exp Bone Diseases, Metabolic/; 2 exp Metabolic Diseases/; 3 or/1–2 1. | Respiratory System; 1 exp Respiratory Tract Diseases/
Infectious Diseases; 1 exp Anti-infective agents/ | Rheumatology; 1 exp Rheumatic Diseases/
| Urology and Nephrology; 1 exp Kidney Diseases/

Example of a complete search: Cardiac and cardiovascular systems

1 exp Heart Diseases/
2 Heart Failure, Congestive/
3 or/1–2
4 limit 3 to animals
5 remove duplicates from 4
6 limit 5 to yr=“1988”
7 limit 5 to yr=“1989”
8 limit 5 to yr=“1990”
9 limit 5 to yr=“1991”
10 limit 5 to yr=“1992”
11 limit 5 to yr=“1993”
12 limit 5 to yr=“1994”
13 limit 5 to yr=“1995”
14 limit 5 to yr=“1996”
15 limit 5 to yr=“1997”
16 limit 5 to yr=“1998”
17 limit 5 to yr=“1999”
18 limit 5 to yr=“2000”
19 limit 5 to yr=“2001”
20 limit 5 to yr=“2002”
21 limit 5 to yr=“2003”
22 limit 5 to yr=“2004”
23 limit 5 to yr=“2005”
24 limit 5 to yr=“2006”
25 limit 5 to yr=“2007”
26 limit 3 to randomized controlled trial
27 limit 3 to clinical trial
28 27 not 26
29 remove duplicates from 28
30 limit 29 to yr=“1988”
31 limit 29 to yr=“1989”
32 limit 29 to yr=“1990”
33 limit 29 to yr=“1991”
34 limit 29 to yr=“1992”
35 limit 29 to yr=“1993”
36 limit 29 to yr=“1994”
37 limit 29 to yr=“1995”
38 limit 29 to yr=“1996”
39 limit 29 to yr=“1997”
40 limit 29 to yr=“1998”
41 limit 29 to yr=“1999”
42 limit 29 to yr=“2000”
43 limit 29 to yr=“2001”
44 limit 29 to yr=“2002”
45 limit 29 to yr=“2003”
46 limit 29 to yr=“2004”
47 limit 29 to yr=“2005”
48 limit 29 to yr=“2006”
49 limit 29 to yr=“2007”
50 limit 3 to randomized controlled trial
51 remove duplicates from 50
52 limit 51 to yr=“1988”
53 limit 51 to yr=“1989”
54 limit 51 to yr=“1990”
55 limit 51 to yr=“1991”
56 limit 51 to yr=“1992”
57 limit 51 to yr=“1993”
58 limit 51 to yr=“1994”
59 limit 51 to yr=“1995”
60 limit 51 to yr=“1996”
61 limit 51 to yr=“1997”
62 limit 51 to yr=“1998”
63 limit 51 to yr=“1999”
64 limit 51 to yr=“2000”
65 limit 51 to yr=“2001”
66 limit 51 to yr=“2002”
67 limit 51 to yr=“2003”
68 limit 51 to yr=“2004”
69 limit 51 to yr=“2005”
70 limit 51 to yr=“2006”
71 limit 51 to yr=“2007”
72 limit 3 to systematic reviews
73 remove duplicates from 72
74 limit 73 to yr=“1988”
75 limit 73 to yr=“1989”
76 limit 73 to yr=“1990”
77 limit 73 to yr=“1991”
78 limit 73 to yr=“1992”
79 limit 73 to yr=“1993”
80 limit 73 to yr=“1994”
81 limit 73 to yr=“1995”
82 limit 73 to yr=“1996”
83 limit 73 to yr=“1997”
84 limit 73 to yr=“1998”
85 limit 73 to yr=“1999”
86 limit 73 to yr=“2000”
87 limit 73 to yr=“2001”
88 limit 73 to yr=“2002”
89 limit 73 to yr=“2003”
90 limit 73 to yr=“2004”
91 limit 73 to yr=“2005”
92 limit 73 to yr=“2006”
93 limit 73 to yr=“2007”
94 limit 3 to guideline
95 remove duplicates from 94
96 limit 95 to yr=“1988”
97 limit 95 to yr=“1989”
98 limit 95 to yr=“1990”
99 limit 95 to yr=“1991”
100 limit 95 to yr=“1992”
101 limit 95 to yr=“1993”
102 limit 95 to yr=“1994”
103 limit 95 to yr=“1995”
104 limit 95 to yr=“1996”
105 limit 95 to yr=“1997”
106 limit 95 to yr=“1998”
107 limit 95 to yr=“1999”
108 limit 95 to yr=“2000”
109 limit 95 to yr=“2001”
110 limit 95 to yr=“2002”
111 limit 95 to yr=“2003”
112 limit 95 to yr=“2004”
113 limit 95 to yr=“2005”
114 limit 95 to yr=“2006”
115 limit 95 to yr=“2007”