# Sample Assessment Worksheet

From Cohort ID 167

Fowlie PW., Prophylactic indomethacin: systematic review and meta-analysis, Arch Dis Child Fetal Neonatal Ed. 1996 Mar;74(2):F81–7.

Cohort Refid | Study refid | Author | Pub Year | MHDA | PMID | Type | On topic? | Eligible N | | Notes
167 | 1 | Mahony | 1985 | 01/05/1985 | 3998921 | Original | | | 104 | N for original is taken from Figure 2 unless otherwise noted
167 | 2 | Ment | 1985 | 01/12/1985 | 3906073 | Original | | | 48
167 | 3 | Vincer | 1987 | 01/11/1987 | 3321891 | Original | | | 30
167 | 4 | Rennie | 1986 | 01/03/1986 | 3516077 | Original | | | 40
167 | 5 | Krueger | 1987 | 01/11/1987 | 3312552 | Original | | | 32
167 | 6 | Hanigan | 1988 | 01/06/1988 | 3373404 | Original | | | 112
167 | 7 | Ment | 1988 | 01/06/1988 | 3373405 | Original | | | 36
167 | 8 | Bandstra | 1988 | 01/10/1988 | 3174314 | Original | | | 199
167 | 9 | Bada | 1989 | 01/10/1989 | 2677294 | Original | | | 141
167 | 10 | Ment | 1994 | 01/06/1994 | 8201485 | Original | | | 61
167 | 11 | Ment | 1994 | 01/04/1994 | 8134206 | Original | | | 431
167 | 12 | Setzer | 1984 | | Not in MEDLINE | Original | | | 59 | from table 2 of refid 167
167 | 13 | Puckett | 1985 | | Not in MEDLINE | Original | | | 32
167 | 14 | Bandstra | 1987 | | Not in MEDLINE | Original | | | 199 | from table 2
167 | 76 | Ohlsson | 2005 | 24/02/2006 | 16235321 | MA | N
167 | 77 | Loe | 2005 | 11/08/2005 | 15994634 | MA | N
167 | 78 | Thomas | 2005 | 21/07/2005 | 15717178 | MA | Y | N
167 | 79 | Simmer | 2005 | 19/07/2005 | 15846747 | MA | N
167 | 80 | Stevens | 2004 | 30/11/2004 | 15266470 | MA | N
167 | 81 | Herrera | 2004 | 29/06/2004 | 14974018 | MA | Y | N | | New comparision b/w prolonged and short course of Indomethacin without definitive results
167 | 82 | Ohlsson | 2004 | 29/06/2004 | 14973955 | MA | N
167 | 83 | Fowlie | 2003 | 10/12/2003 | 14602691 | MA | Y | Y
167 | 84 | Cooke | 2003 | 28/07/2003 | 12804488 | MA | Y | N | | no new study
167 | 85 | Shah | 2003 | 27/03/2003 | 12535425 | MA | N
167 | 86 | Brion | 1999 | 26/07/1999 | 10353408 | MA | Y | N
167 | 87 | Rubino | 1997 | 05/06/1997 | 9165939 | MA | Y | N
167 | 88 | Clark | 1996 | 03/01/1997 | 8951253 | MA | N
167 | 89 | Clyman | 1996 | 26/06/1996 | 8627430 | MA | Y
167 | 74 | Simko | 1994 | 01/06/1994 | 8169675 | Candidate
167 | 72 | Rush | 1994 | 29/09/1994 | 8071758 | Candidate
167 | 71 | Hammerman | 1995 | 27/02/1995 | 7838642 | Candidate
167 | 70 | Ment | 1995 | 14/04/1995 | 7892866 | Candidate
167 | 69 | Corbet | 1995 | 07/07/1995 | 7776110 | Candidate
167 | 68 | Malloy | 1995 | 11/10/1995 | 7666265 | Candidate
167 | 66 | Bernstein | 1996 | 07/06/1996 | 8618177 | Candidate
167 | 67 | Van | 1995 | 07/06/1996 | 8618789 | Candidate
167 | 65 | Couser | 1996 | 26/06/1996 | 8627434 | Candidate | Y | Y | 90 | Identified in ref id 83 and included in its pooled stats
167 | 64 | Ment | 1996 | 01/07/1996 | 8632956 | Candidate
167 | 63 | Silver | 1996 | 15/08/1996 | 8677067 | Candidate
167 | 62 | Rastogi | 1996 | 29/08/1996 | 8692619 | Candidate
167 | 61 | Ment | 1996 | 04/12/1996 | 8885951 | Candidate
167 | 60 | Gerstmann | 1996 | 03/01/1997 | 8951252 | Candidate
167 | 59 | Yaseen | 1997 | 12/05/1997 | 9078828 | Candidate | Y | Y | 27 | Identified in ref id 83 and included in its pooled stats
167 | 58 | Van | 1997 | 26/06/1997 | 9175948 | Candidate
167 | 57 | Allan | 1997 | 10/07/1997 | 9193243 | Candidate
167 | 56 | Hudak | 1997 | 21/07/1997 | 9200358 | Candidate
167 | 55 | Parilla | 1997 | 04/08/1997 | 9215169 | Candidate
167 | 54 | Romagnoli | 1997 | 11/09/1997 | 9284854 | Candidate
167 | 53 | Keszler | 1997 | 14/10/1997 | 9310511 | Candidate
167 | 52 | Chugh | 1997 | 13/11/1997 | 9332109 | Candidate
167 | 50 | Su | 1998 | 30/04/1998 | 9553290 | Candidate
167 | 49 | Morales | 1998 | 21/05/1998 | 9568218 | Candidate
167 | 48 | Ment | 1998 | 14/08/1998 | 9714645 | Candidate
167 | 51 | Yeh | 1997 | 10/09/1998 | 9310536 | Candidate
167 | 47 | rroyo-Cabrales | 1998 | 12/11/1998 | 9775459 | Candidate
167 | 46 | Anand | 1999 | 16/04/1999 | 10201714 | Candidate
167 | 45 | Tammela | 1999 | 25/05/1999 | 10228288 | Candidate
167 | 44 | Kothadia | 1999 | 22/07/1999 | 10390255 | Candidate
167 | 43 | Vohr | 1999 | 26/08/1999 | 10405190 | Candidate
167 | 42 | Panter | 1999 | 02/09/1999 | 10430197 | Candidate
167 | 41 | Kopelman | 1999 | 12/10/1999 | 10484801 | Candidate
167 | 40 | Baenziger | 1999 | 11/01/2000 | 10592922 | Candidate
167 | 36 | Patel | 2000 | 20/01/2000 | 10625080 | Candidate
167 | 35 | Ment | 2000 | 22/03/2000 | 10699097 | Candidate
167 | 39 | Su | 1999 | 23/03/2000 | 10525023 | Candidate
167 | 38 | Supapannachart | 1999 | 05/04/2000 | 10730525 | Candidate | Y | Y | 30 | Identified in ref id 83 and included in its pooled stats
167 | 34 | Couser | 2000 | 21/06/2000 | 10850507 | Candidate | Y | N | | Outcome not considered
167 | 33 | Van | 2000 | 07/09/2000 | 10974130 | Candidate
167 | 32 | De Carolis | 2000 | 14/09/2000 | 10834523 | Candidate
167 | 37 | Sanghvi | 1999 | 05/01/2001 | 10740301 | Candidate
167 | 30 | Stark | 2001 | 11/01/2001 | 11150359 | Candidate
167 | 29 | Wardle | 2001 | 22/02/2001 | 11124916 | Candidate
167 | 28 | Van | 2001 | 05/04/2001 | 11174617 | Candidate
167 | 31 | Dani | 2000 | 31/05/2001 | 11106052 | Candidate
167 | 27 | Schmidt | 2001 | 05/07/2001 | 11430325 | Candidate | Y | Y | 1202 | Identified in ref id 83 and included in its pooled stats
167 | 26 | Vermont | 2001 | 18/10/2001 | 11533345 | Candidate
167 | 25 | Schmidt | 2002 | 07/10/2002 | 12241754 | Candidate
167 | 24 | Christmann | 2002 | 22/11/2002 | 12061361 | Candidate
167 | 23 | Lago | 2002 | 04/02/2003 | 12014386 | Candidate | Y | N
167 | 22 | Supapannachart | 2002 | 12/02/2003 | 12549803 | Candidate | Y | N
167 | 21 | Vohr | 2003 | 18/04/2003 | 12671149 | Candidate | Y | N
167 | 20 | Lee | 2003 | 03/10/2003 | 12897285 | Candidate | Y | N
167 | 19 | Simons | 2003 | 25/11/2003 | 14612478 | Candidate | N
167 | 18 | Schreiber | 2003 | 08/12/2003 | 14645637 | Candidate | N
167 | 17 | Osborn | 2003 | 10/12/2003 | 14602694 | Candidate | Y | N
167 | 16 | Chotigeat | 2003 | 05/02/2004 | 14700149 | Candidate | Y | N
167 | 15 | Su | 2003 | 26/02/2004 | 14651538 | Candidate | Y | N
167 | 14 | Kumar | 2004 | 05/10/2004 | 15235161 | Candidate | Y | Y | 115
167 | 13 | Gournay | 2004 | 15/12/2004 | 15567009 | Candidate | N
167 | 12 | Van | 2004 | 15/12/2004 | 15567010 | Candidate | N
167 | 11 | Vila-Vazqu | 2004 | 18/03/2005 | 15298714 | Candidate | N
167 | 10 | Mestan | 2005 | 12/07/2005 | 16000353 | Candidate | N
167 | 9 | Van Meurs | 2005 | 12/07/2005 | 16000352 | Candidate | N
167 | 8 | Hall | 2005 | 27/09/2005 | 15867047 | Candidate | N
167 | 6 | Bell | 2005 | 10/11/2005 | 15930233 | Candidate | N
167 | 7 | Dani | 2005 | 10/11/2005 | 15930213 | Candidate | N
167 | 5 | Gimeno | 2005 | 07/12/2005 | 16219273 | Candidate | Y | N
167 | 4 | Olney | 2005 | 29/12/2005 | 16041635 | Candidate | N
167 | 3 | Zanardo | 2005 | 19/01/2006 | 16260891 | Candidate | Y | N
167 | 1 | Mercer | 2006 | 10/05/2006 | 16585320 | Candidate | N
167 | 2 | Adamska | 2005 | 25/05/2006 | 16547381 | Candidate | Y | N
167 | | Morales-Suarez | 1994 | | Not in MEDLINE | Nomination | Y | Y | 80 | Identified in Cochrane version of Fowlie 2003. Analysis 01.02
167 | | Domanico | 1994 | | Not in MEDLINE | Nomination | Y | Y | 100 | Fowlie 2003 Analysis 01.04

Note candidate studies after the last search date of ref id 83 were screened.