# Sample Subject Searches

Examples of subject searches and how search features are scored. The last line of each search retrieved the Clinical Query set. The second from last line retrieves the Core Clinical Journal RCT set. The third from last line retrieves the meta-analysis set.

Eikelboom JW Quinlan DJ and Douketis JD, Extended-duration prophylaxis against venous thromboembolism after total hip or knee replacement: a meta-analysis of the randomised trials. Lancet. 2001 Jul 7;358(9275):9–15.

Feature scoring: 5 terms and exploded terms (lines 1,2, 3). The clinical query used is the sensitivity query.

1 exp Heparin/
2 exp Warfarin/
3 exp Venous Thrombosis/
4 Arthroplasty, Replacement, Knee/
5 Arthroplasty, Replacement, Hip/
6 1 or 2
7 4 or 5
8 3 and 6 and 7
9 limit 8 to (yr=“2000 - 2006” and meta analysis)
10 limit 8 to (“core clinical journals (aim)” and yr=“2000 - 2006” and randomized controlled trial)
11 limit 8 to (“therapy (specificity)” and yr=“2000 - 2006” )

Fowlie PW., Prophylactic indomethacin: systematic review and meta-analysis, Arch Dis Child Fetal Neonatal Ed. 1996 Mar;74(2):F81–7.

Feature scoring: 4 terms, exploded terms (line 1) and free text terms (line 3)

1 exp Indomethacin/
2 Ductus Arteriosus, Patent/
3 Cerebral Hemorrhage/ or intraventricular hemorrhage.mp.
4 2 or 3
5 1 and 4
6 limit 5 to (yr=“1994 - 2006” and meta analysis)
7 limit 5 to (“core clinical journals (aim)” and yr=“1994 - 2006” and randomized controlled trial)
8 limit 5 to (“therapy (optimized )” and yr=“1994 - 2006”)

Bucher HC, Hengstler, P, Schindler C, and Guyatt GH. Percutaneous transluminal coronary angioplasty versus medical treatment for non-acute coronary heart disease: meta-analysis of randomised controlled trials, BMJ. 2000 Jul 8;321(7253):73–7.

Feature scoring: 2 terms, starred terms (lines 1 and 2) and subheadings (line 2).

1 *Angioplasty, Transluminal, Percutaneous Coronary/
2 *Myocardial Infarction/tu, dt
3 1 and 2
4 limit 3 to (yr=“1995 - 2006” and meta analysis)
5 limit 3 to (“core clinical journals (aim)” and yr=“1995 - 2006” and randomized controlled trial)
6 limit 3 to (“therapy (optimized )” and yr=“1995 - 2006”)