# Appendixes

Appendix A Definitions and Criteria for Signals for Updating

Appendix B Examples of Systematic Reviews with Qualitative Signals for Potentially Invalidating Changes in Evidence

Appendix C Sample Subject Searches

Appendix D Sample Assessment Worksheet

Appendix E Searches by Clinical Area

Appendix F Growth of the Literature by Clinical Area

Appendix G Survey Instrument