# References

1 Rosenthal M, Milstein A. Awakening Consumer Stewardship of Health Benefits: Prevalence and Differentiation of New Health Plan Models. Health Services Research. 2004 2004/08/02/;39(4):1055–70.
2 Rosenthal M, Hsuan C, Milstein A. A report card on the freshman class of consumer-directed health plans. Health Affairs. Nov-Dec. 2005;24(6):1592-600. [pmid: 16284033].
3 Herzlinger RE. Let's put consumers in charge of health care. Harvard Business Review. 2002 123. Jul. 2002;80(7):44-50.
4 Rand: Buntin MBD, C.; Haviland, A.; Lurie, N.; Kapur, K.; Marquis, M.S. Consumer-Directed Health-Plans: Implications for Health Care Quality and Cost. Oakland, CA: Rand; 2005 June. Report No.: ISBN: 1-932064-89-3.
5 Gabel JR, Lo Sasso AT, Rice T. Consumer-driven health plans: are they more than talk now? Health Affairs. 2002 Jul–Dec;Suppl Web Exclusives:W395–407.
6 GAO, United States Government Accountability Office. Medical Savings Accounts. Results From Surveys of Insurers. Report to Congressional Committees. Washington, DC: Submitted by: Westat in affilation with The Barents Group, Project HOPE and HayGroup; 1998 Dec 31. Report No.: GAO/HEHS-99-34.
7 Kaiser Family Foundation and Health Research & Educational Trust. Employer Health Benefits 2005 Annual Survey; 2005. Report No.: 7315 (full report) (#7316 - summary of findings).
8 Hewitt Associates. Research Report. Take Control: An Employer's Guide to Consumer-Driven Health Care 2006; 2006. Report No.: SR-0170-001-EN.
9 Gabel JR, Whitmore H, Rice T, et al. Employers' contradictory views about consumer-driven health care: results from a national survey. Health Affairs. 2004 Jan–Jun;Suppl Web Exclusives:W4-210-8.
10 GAO, United States Government Accountability Office. Federal Employees Health Benefits Program. Early Experience with a Consumer-Directed Health Plan. Report to the Ranking Minority Member Committee on Finance, US Senate. Washington, DC; 2005 November. Report No.: GAO-06-143.
11 Remler DK, Glied SA. How much more cost sharing will health savings accounts bring?. Health Aff (Millwood). Jul-Aug. 2006;25(4):1070-8. [pmid: 16835188].
12 Marshall MN, Shekelle PG, et al. The Public Release of Performance Data: What Do We Expect To Gain? A Review of the Evidence. Journal of the American Medical Association. 2000;283(14):1866-74. [pmid: 10770149].
13 Schauffler HH, Mordavsky JK. Consumer Reports in Health Care: Do They Make A Difference?. Annual Review of Public Health. 2001;22:69-89.
14 Werner RM, Asche DA. The Unintended Consequences of Publicly Reporting Quality Information. JAMA. 2005;293(10):1239-44. [pmid: 15755946].
15 Hibbard JH, Peters E. Supporting Informed Consumer Health Care Decisions: Data Presentation Approaches that Facilitate the Use of Information in Choice. Annual Review of Public Health. 2003;24:413-33.
16 Hellinger FJ. The Effect of Managed Care on Quality: A Review of Recent Evidence. Archives of Internal Medicine. April 27. 1998;158(8):833-41. [pmid: 9570168].
17 Hutchinson B, Birch S, Hurley J, et al. Do Physician-Payment Mechanisms Affect Hospital Utilization? A Study of Health Service Organizations in Ontario. Canadian Medical Association Journal. 1996;154(5):653-61. [pmid: 8603321]. [pmcid: 1487544].
18 Dudley RA, Frolich A, Robinowitz DL, et al. Strategies To Support Quality-based Purchasing: A Review of the Evidence. Technical Review 10. Prepared by the Stanford-University of California San Francisco Evidence-based Practice Center under Contract No. 290-02-0017; 2004 July. Report No.: Agency for Healthcare Research and Quality (AHRQ) Publication No. 04-0057.
19 Andersen RM. Revisiting the Behavioral Model and Access to Medical Care: Does it Matter? Journal of Health and Social Behavior.36(1):1–10.
20 Phelps CE. Health Economics. Second ed. Reading, M.A.: Addison Wesley 1997.
21 Feldstein PJ. Health Care Economics. Fourth ed. Albany, NY: Delmar Publishers Inc; 1993.
22 Zweifel P, Manning WG. Moral Hazard and Consumer Incentives in Health Care. In: Culyer AJ, Newhouse JP, editors. Handbook of Health Economics. First ed. Amsterdam, Lausanne, New York, Oxford, Shannon, Singapore, Tokyo: Elsevier; 2000. p. 409–59.
23 Stigler G. The Economics of Information. The Journal of Political Economy. 1961:213–25.
24 Haas-Wilson D. Consumer Information and Providers' Reputations: An Empirical Test in the Market for Psychotherapy. Journal of Health Economics. 1991;9:321-33. [pmid: 10107849].
25 Bundorf MK, Wagner TH, et al. Who Searches the Internet for Health Information?. Health Services Research. 2006;41(3):819-36. [pmid: 16704514]. [pmcid: 1713205].
26 Bundorf MK. Employee Demand for Health Insurance and Employer Health Plan Choices. Journal of Health Economics. 2002;21:65-88. [pmid: 11845926].
27 Scanlon DP, Chernew M, Lave JR. Consumer health plan choice: current knowledge and future directions. Annual Review of Public Health. 1997;18:507-28.
28 Royalty AB, Solomon N. Health Plan Choice: Price Elasticities in a Managed Competitive Setting. The Journal of Human Resources. 1999;34(1):1-41.
29 Beaulieu ND. Quality Information and Consumer Health Plan Choices. Journal of Health Economics. 2002;21:43-63. [pmid: 11845925].
30 Wedig GJ, Tai-Seale M. The Effect of Report Cards on Consumer Choice in the Health Insurance Market. Journal of Health Economics. 2002;21:1031-48. [pmid: 12475124].
31 Lee TH, Zapert K. Do high-deductible health plans threaten quality of care?. New England Journal of Medicine. Sep 22. 2005;353(12):1202-4. [pmid: 16177246].
32 Yoshisue K, Hironaga K, et al. Reduction of 5-Flourouracil (5-FU) Gastrointestinal (GI) Toxicity Resulting From the Protection of Thymidylate Synthase (TS) in GI Tissue by Repeated Simultaneous Administration of Potassium Oxonate (Oxo) in Rats. Cancer Chemotherapy and Pharmacology. 2000;46(1):51-6. [pmid: 10912578].
33 Roseman C. The Politics of HSA Cost-Containment Efforts: A Symposium. Journal of Health and Human Resources Administration. 1981;4(1):4-9. [pmid: 10253198].
34 Zwanziger J, Mooney C. Has Price Competition Changed Hospital Revenues and Expenses in New York. Inquiry. 2005;42(2):183-92. [pmid: 16196315].
35 Kralewski JE, Wingert TD, et al. Factors Related to the Provision of Hospital Discounts for HMO Patients. Health Services Research. 1992;27(2):133-53. [pmid: 1592603]. [pmcid: 1069870].
36 Cutler DM. The Economic Impacts of the Tobacco Settlement. Journal of Policy Analysis and Management. 2002;21(1):1-19. [pmid: 11887906].
37 Cardon J, Showalter H. An Examination of Flexible Spending Accounts. Journal of Health Economics. Nov. 2001;20(6):935-54. [pmid: 11758053].
38 Green W. Consumer-Directed Advertising of Contraceptive Drugs: The FDA, Depo-Provera and Product Liability. Food and Drug Law Journal. 1995;50(4):553-67. [pmid: 10343019].
39 Benjamin AE. Consumer-Directed Services at Home: A New Model for Persons with Disabilities. Health Affairs. 2001;20(6):80-95. [pmid: 11816693].
40 Barr MD. Medical Savings Accounts in Singapore: A Critical Inquiry. Journal of Health Politics, Policy & Law. 2001;26(4):709-26.
41 Dixon A. Are medical savings accounts a viable option for funding health care?. Croatian Medical Journal. Aug. 2002;43(4):408-16. [pmid: 12187518].
42 Frates J, Severoni E. Consumer-directed health plans: enrollee views, early employer experience. Managed Care. Jun. 2005;14(6):58-60. [pmid: 16044890].
43 Pauly M, Percy A, Rosenbloom JS, et al. What benefit specialists think about medical savings account options for large firms. Benefits Quarterly. 2000;16(3):39-46. [pmid: 11183600].
44 Zabinski D, Selden TM, Moeller JF, et al. Medical savings accounts: microsimulation results from a model with adverse selection. Journal of Health Economics. Apr. 1999;18(2):195-218. [pmid: 10346353].
45 Keeler EB, Malkin JD, Goldman DP, et al. Can medical savings accounts for the nonelderly reduce health care costs?[see comment]. JAMA. Jun 5. 1996;275(21):1666-71. [pmid: 8637141].
46 Ozanne L. How Will Medical Savings Accounts Affect Medical Spending? Inquiry. 1996 1996///Fall;33(3):225–36.
47 Pauly MV, Herring BJ. An Efficient Employer Strategy for Dealing with Adverse Selection in Multiple-Plan Offerings: An MSA Example. Journal of Health Economics. 2000 2000/07//;19(4):513–28.
48 Feldman R, Parente ST, Abraham J, et al. Health savings accounts: early estimates of national take-up. Health Affairs. Nov-Dec. 2005;24(6):1582-91. [pmid: 16284032].
49 Glied SA, Remler DK. The effect of health savings accounts on health insurance coverage. Issue Brief (Commonwealth Fund). 2005 Apr(811):1–8
50 Cross M. Medtronic, Early Adopter of CDHP, More Than Satisfied With Result. Managed Care. 2005;14(10):71-2. [pmid: 16277198].
51 Jensen GA, Morlock RJ, et al. Why medical savings accounts deserve a closer look. Journal of American Health Policy. May-Jun. 1994;4(3):14-23. [pmid: 10134318].
52 Lo Sasso AT, Rice T, Gabel JR, et al. Tales from the new frontier: pioneers' experiences with consumer-driven health care. Health Services Research. Aug. 2004;39(4 Pt 2):1071-90. [pmid: 15230912]. [pmcid: 1361054].
53 Wilensky GR. Consumer-directed health plans a new force in health insurance?. Healthcare Financial Management 2005. Oct. 2005;59(10):34.
54 Newhouse JP. Consumer-directed health plans and the RAND Health Insurance Experiment. Health Affairs. Nov-Dec. 2004;23(6):107-13. [pmid: 15584103].
55 Robinson JC. Health savings accounts—the ownership society in health care. New England Journal of Medicine. Sep 22. 2005;353(12):1199-202. [pmid: 16177245].
56 Parente ST, Feldman R, Christianson JB. Evaluation of the Effect of a Consumer-Driven Health Plan on Medical Care Expenditures and Utilization. Health Services Research. 2004 2004/08/02/;39(4):1189–209.
57 Christianson JB, Parente ST, Feldman R. Consumer Experiences in a Consumer-Driven Health Plan. Health Services Research. 2004 2004/08/02/;39(4):1123–39.
58 Parente ST, Feldman R, Christianson JB. Employee Choice of Consumer-Driven Health Insurance in a Multiplan, Multiproduct Setting. Health Services Research. 2004 2004/08/02/;39(4):1091–111.
59 Fowles JB, Kind EA, Braun BL, et al. Early experience with employee choice of consumer-directed health plans and satisfaction with enrollment. Health Services Research. Aug. 2004;39(4 Pt 2):1141-58. [pmid: 15230917].
60 Tollen LA, Ross MN, Poor S. Risk Segmentation Related to the Offering of a Consumer-Directed Health Plan: A Case Study of Humana Inc. Health Services Research. 2004 2004/08/02/;39(4):1167–87.
61 Minicozzi A, et al. Medical savings accounts: what story do the data tell?. Health Affairs. Jan-Feb. 2006;25(1):256-67. [pmid: 16403762].
62 Fronstin P, Collins SR. Early experience with high-deductible and consumer-driven health plans: findings from the EBRI/Commonwealth Fund Consumerism in Health Care Survey. EBRI Issue Brief. 2005 Dec(288):4–28.
63 Claxton G, Gabel JR, Gil I. What High-Deductible Plans Look Like: Findings From a National Survey of Employers, 2005. Health Affairs. 2005 Published online 14 Sept. 2005 24(5):1273–80.
64 Romano PS, Rainwater J. Feasibility and Use of Quality Indicators for Public Reporting: Literature Review of Public Reporting Systems; 2003.